# Introduction

The National High Blood Pressure Education Program (NHBPEP), coordinated by the National Heart, Lung, and Blood Institute (NHLBI) of the National Institutes of Health, was established in 1972. The program is succeeding in its mission of increasing awareness, prevention, treatment, and control of hypertension (Table 1). From the 1976-80 National Health and Nutrition Examination Survey (NHANES II) to the 1988-91 survey (NHANES III, phase 1), the percentage of Americans who are aware that they have high blood pressure increased from 51 to 73 percent.^1^ Among persons with hypertension, treatment has increased during that same period from 31 to 55 percent. The number of persons with high blood pressure controlled to below 140/90 mm Hg has increased from 10 percent in the NHANES II to 29 percent in the NHANES III, phase 1.^1^

Table 1 Trends in the Awareness, Treatment, and Control of High Blood Pressure in Adults: United States, 1976-94*

| NHANES II | NHANES III | NHANES III
| (1976-80) | (Phase 1) | (Phase 2)
| | 1988-91 | 1991-94
Awareness | 51% | 73% | 68.4%
Treatment | 31% | 55% | 53.6%
Control^†^ | 10% | 29% | 27.4%

* Data are for adults age 18 to 74 years with SBP of 140 mm Hg or greater, DBP of 90 mm Hg or greater, or taking antihypertensive medication.

† SBP below 140 mm Hg and DBP below 90 mm Hg.

Source: Burt V et al.^1^ and unpublished NHANES III, phase 2, data provided by the Centers for Disease Control and Prevention, National Center for Health Statistics.^2^

These changes have contributed to dramatic reductions in morbidity and mortality attributable to hypertension. For example, age-adjusted death rates from stroke have declined by nearly 60 percent and from coronary heart disease (CHD) by 53 percent. These trends are evident in men and women and in African Americans and whites (Figures 1 and 2). The benefit of reduction in stroke mortality is particularly striking in women age 50 and older: one-half of the benefit among white women and nearly two-thirds of the benefit among African American women can be attributed to the fall in blood pressure.^2^ These improvements are consistent with the decline in disability among older Americans and have important implications for reducing national health care costs.^3^

Figure 1

Percent Decline in Age-Adjusted Mortality Rates for Stoke by Sex and Race: United States, 1972-94

Figure 2

Percent Decline in Age-Adjusted Mortality Rates for CHD by Sex and Race: United States, 1972-94

However, since publication of the Fifth Report of the Joint National Committee on Detection, Evaluation, and Treatment of High Blood Pressure (JNC V),^4^ these dramatic improvements have slowed; since 1993, age-adjusted stroke rates have risen slightly, and the slope of the age-adjusted rate of decline in CHD appears to be leveling.^5^ Furthermore, rates have increased for both the incidence of end-stage renal disease, for which high blood pressure is the second most common antecedent,^6^ and the prevalence of heart failure, wherein the large majority of patients have antecedent hypertension^7^ (Figures 3 and 4). Moreover, hypertension control rates have not continued to improve (NHANES III, phase 2) (Table 1). If awareness, treatment, and control rates had continued the trend established between 1976-80 and 1988-91, there would have been an increase in 1991-94 in awareness to 76.2 percent, in treatment to 59.6 percent, and in control to 31.2 percent instead of the levels shown in Table 1.^8^ In addition, recent reports from Minnesota have shown a decrease in awareness, treatment, and control of hypertension.^9–11^ Furthermore, the average blood pressure of a cohort in Iowa that has been serially evaluated and age-adjusted has risen.^12^ Progress has been steady toward reaching the U.S. Department of Health and Human Services goals for heart disease and stroke, but additional efforts are necessary to meet these objectives by the year 2000.^13^

Figure 3

Incidence Rates per Million Population of Reported End-Stage Renal Disease Therapy, 1982-95, Adjusted for Age, Race, and Sex

Figure 4

Prevalence of Heart Failure, by Age, 1976-80 and 1988-91

Organization and Method

The NHBPEP Coordinating Committee consists of representatives from 38 national professional, public, and voluntary health organizations and 7 Federal agencies. After this committee ascertained the need for a JNC VI report, NHLBI staff conducted and reported on focus groups among primary care physicians regarding the nature and purpose of national guidelines and to determine how the guidelines could best be structured to help busy clinicians. These focus groups recommended that guidelines for busy clinicians must be succinct and user-friendly.^15^

The preparation of the JNC VI report was coordinated by an executive committee, composed of the JNC VI chair, the chairs of the individual chapter writing teams, and the chairs of four previous JNC reports—a total of nine individuals. Contributions were obtained from multidisciplinary experts from the fields of medicine, nursing, nutrition, pharmacy, and public health, whose submissions were condensed, assembled, reviewed, and edited by the executive committee.

The contributing team members were asked to review the English-language literature on hypertension published since January 1992 for their sections. Previous literature was reviewed in earlier reports. However, in some instances, earlier literature was included to strengthen evidence-based recommendations. Inclusion decisions were made by the same experts. The data have been synthesized into recommendations by consensus of the executive committee, which considered the nature and quality of the study designs and analyses. Additional experts in specific areas were consulted as needed. Each contributor had the opportunity to review and comment on the entire document.

The executive committee met in person on six occasions, conducted several teleconferences, and had extensive correspondence. The executive committee used a modified nominal group process to identify and resolve issues.^16^ On behalf of the executive committee, the JNC VI chair reported to the NHBPEP Coordinating Committee, which reviewed the document at its spring 1997 meeting and submitted written comments to the executive committee. The Coordinating Committee had the final vote of approval on the report.

The development of this report was funded entirely by the NHLBI. The executive committee, contributors, reviewers, and Coordinating Committee members served as volunteers and were remunerated only for travel expenses pertaining to Coordinating Committee and executive committee meetings.

Heart disease and stroke remain the first and third leading causes of death, respectively, in the United States and impose an enormous financial and social burden on Americans (more than $259 billion in direct and indirect costs).^5^ In particular, the continued high prevalence of hypertension and hypertension-related complications of stroke, heart failure, and end-stage renal disease in the southeastern United States makes these diseases a public health concern for all who reside in this region, particularly African Americans.^14^ These disturbing trends support the need to enhance public and professional education and to translate the results of research into improved health.

## Evidence Base

The studies that provided evidence supporting the recommendations for prevention and treatment (chapters 3 and 4) were classified by the writers and staff and reviewed by the chapter chairs. For the purpose of this report, the classification was adapted from Last and Abramson^17^ as follows:

M meta-analyses—an analysis of a compendium of experimental studies;

Ra randomized controlled trials—also known as experimental studies;

Re retrospective analyses—also known as case control studies;

F prospective followup—also known as cohort studies, including historical cohort studies and long-term followup;

X cross-sectional population studies—also known as prevalence studies;

Pr previous review or position statements; and

C clinical interventions (nonrandomized).

These symbols follow the references in the reference list of the report as well as the citations in chapters 3 and 4 in the text. Some references may have more than one code depending on the component of the study cited (e.g., a randomized controlled trial having a long-term followup).

## Clinical Policy

In considering the evidence to formulate clinical policy, absolute rather than relative changes were considered because the absolute benefit derived from treating hypertension depends on the absolute risk; that is, those at greater risk will achieve greater benefit^18^ (Figure 5). Information from randomized controlled trials (RCTs) indicates the reduction in the number of cardiovascular events in a known time period among patients with defined hypertension. The inverse of absolute risk reduction is the number of patients needed to be treated to prevent one event.^19^ In the clinical policy presented below, the JNC report emphasizes interventions that have been shown to reduce the incidence of adverse clinical outcomes, mostly from RCTs, which remain the best source of evidence. Nonetheless, RCTs do have limitations,^20–23^ which are summarized as follows:

Figure 5

Comparison of Proportionate (Relative) and Absolute Benefit from Reduction in the Incidence of Stroke

- RCTs are of short to moderate duration, and benefits of hypertension treatment accrue over a lifetime.
- Most RCTs do not include a true placebo group, thus underestimating the beneficial effect of the trials. For example, the control group may include those receiving treatment according to protocol or by their personal clinician after commencement of the trial (the drop-in effect), the true effects of the treatment may be diluted by those who stopped it (the drop-out effect), or the trial is a comparison of two forms of therapy.
- RCTs do not truly represent clinical practice because some patients (typically those at higher risk) are excluded from trials, such as patients with recent stroke or myocardial infarction or patients with a specific need for the study drug (e.g., beta-blockers). Thus, the study cohort may be at lower risk than the general population.
- The average reduction in blood pressure in RCTs is modest and underestimates the additional benefits that accrue from larger decreases in blood pressure, which may be seen in individual patients.
- RCTs focus primarily on a priori endpoints and not necessarily on other benefits of therapy (e.g., prevention of progression to disease endpoints, improved quality of life, reduced impact of comorbid conditions, fewer workdays missed because of illness).
- Finally, the methods used in constructing meta-analyses vary by author; thus, the conclusions (e.g., number of patients needed to treat to prevent one event) may differ.

Because of these limitations, the executive committee extrapolated treatment effects beyond the duration of the clinical trials based on physiological and epidemiological data.

## Public Health Challenges of Hypertension

The prevention and treatment of hypertension represent major public health challenges for the United States as we enter the new millennium. These are the challenges:

- Prevent the rise of blood pressure with age. If the U.S. population retained the average blood pressure levels of young adults, there would be less cardiovascular disease.
- Decrease the existing prevalence of hypertension. Approximately 50 million adult Americans have hypertension.^24^
- Increase hypertension awareness and detection. A large number of adult Americans with hypertension are still unaware that they have high blood pressure.^24^
- Improve control of hypertension. Nearly three-fourths of adult Americans with hypertension are not controlling their blood pressure to below 140/90 mm Hg.^24^
- Reduce cardiovascular risks. Most persons with hypertension have additional risk factors for cardiovascular disease.^25^
- Increase recognition of the importance of controlled isolated systolic hypertension. The majority of persons with isolated systolic hypertension are not adequately controlling their blood pressure despite persuasive data from clinical trials documenting the benefit of treatment.^24^
- Improve recognition of the importance of high-normal blood pressure. The impact of high-normal blood pressure—systolic blood pressure of 130 to 139 mm Hg and diastolic blood pressure of 85 to 89 mm Hg—on the development of hypertension and target organ damage remains unappreciated.^26,^ ^27^
- Reduce ethnic, socioeconomic, and regional variations in hypertension. Differences remain in the prevalence of hypertension, high-normal blood pressure, and cardiovascular events in different ethnic and socioeconomic groups and geographic regions.^14^
- Improve opportunities for treatment. Well-tolerated and affordable treatment options, including both lifestyle modifications and pharmacologic treatment, are not being universally applied.^14^
- Enhance community programs. In the face of declining budgets, community programs are challenged to increase activities to prevent high blood pressure and serve more persons with hypertension.

## Community Programs

During its 25-year history, the NHBPEP has developed a broad array of community-based activities designed to promote prevention, raise awareness, screen for high blood pressure and other cardiovascular risk factors, improve adherence to therapy, and reduce morbidity and mortality. Community program activities are addressed fully in NHLBI publications and other documents.^28–39^

## Summary

- Hypertension awareness, treatment, and control rates have increased over the past 3 decades. The rates of increase have lessened since publication of the JNC V report.
- Age-adjusted mortality rates for stroke and coronary heart disease declined during this time but now appear to be leveling.
- The incidence of end-stage renal disease and the prevalence of heart failure are increasing.
- Randomized controlled trials provide the best method of estimating the benefit of treatment and source of information for clinical policy, but they do have limitations.
- Prevention and treatment of hypertension and target organ disease remain important public health challenges that must be addressed.