# High Blood Pressure Reports and Materials From the National Heart, Lung, and Blood Institute

Contact the NHLBI Information Center for the price and availability of the publications listed below.

NHLBI Information Center

P.O. Box 30105

Bethesda, MD 20824-0105

Telephone: (301) 251-1222

Fax: (301) 251-1223

Update of the Task Force Report on High Blood Pressure in Children and Adolescents. Includes revised normative blood pressure charts based on height percentiles, age, and gender beginning at 1 year of age. Also includes new charts for selecting antihypertensive drug therapy. (#3790)

Working Group Report on Primary Prevention of Hypertension. Examines the causes of high blood pressure and recommends prevention measures. Discusses sodium intake, weight, alcohol consumption, physical activity, and stress in relationship to the development of hypertension. (#2669)

Working Group Report on Hypertension in Diabetes. Guides clinicians in the care of persons with hypertension and diabetes. Addresses epidemiological, diagnostic, and clinical considerations as well as special concerns, such as kidney disease, sexual dysfunction, obesity, and pregnancy. (#3530)

Controlling High Blood Pressure in Older Women: Clinical Reference Manual. Assists clinicians in the care of older patients with high blood pressure, especially women. Presents the benefits of antihypertensive therapy, detection, evaluation, and treatment strategies. Includes charts to help clinicians improve patient adherence to therapy and select antihypertensive drug therapy.

1995 Update of the Working Group Reports on Chronic Renal Failure and Renovascular Hypertension. Alerts clinicians to the increasing annual incidence of end-stage renal disease (ESRD) and reviews the current knowledge about high blood pressure and chronic renal failure. Discusses therapeutic strategies to reduce the risk of ESRD, hypertensive nephrosclerosis, diabetes, and other forms of chronic renal failure. (#3791)

## ENHANCE YOUR PATIENT EDUCATION WITH NHLBI HIGH BLOOD PRESSURE MATERIALS

High Blood Pressure: Treat It for Life. Helps patients take action against high blood pressure, including losing weight if overweight, increasing physical activity, choosing foods lower in salt and sodium, limiting alcohol, and taking medication as prescribed. Includes a sample walking program, menu ideas, and recipes. (#3312)

Eat Right To Help Lower Your High Blood Pressure. Presents practical information in an easy-to-read (5th-grade level) conversational text brochure featuring large type and colorful illustrations. Helps patients reduce high blood pressure by losing weight, being more active, drinking less alcohol, and using less salt and sodium. (#3289)

Controlling High Blood Pressure: A Woman's Guide. Explains how high blood pressure affects women's health and describes the simple steps used to prevent and control high blood pressure as well as the types of medication used to treat the condition. Includes a handy table of generic names of blood pressure medications and a chart for recording blood pressure readings. (#55-820)

Healthy Heart Handbook for Women. Tells women of all ages (both with and without heart disease) how to take action to make their hearts healthier. Discusses how to talk to the doctor, blood pressure and blood cholesterol, physical activity, weight loss, hormone replacement therapy, heart attack symptoms, heart-healthy eating, and more. (#2720)

Exercise and Your Heart—A Guide to Physical Activity. Provides patients with information on the effects of physical activity on their heart, and practical guidelines for starting and staying on their own exercise program. Discusses the benefits, risks, and common myths about exercise and includes tips and sample activity programs. (#1677)

Facts About How To Prevent High Blood Pressure. Describes what high blood pressure is and what happens when blood pressure is high. Includes information on the steps to take to prevent high blood pressure including a sample walking program, food selection and preparation tips, and weight control. (#3281)

Stay Up-to-Date Online

- Visit our Web site at www.nhlbi.nih.gov/nhlbi/nhlbi.htm.
- Learn of new publications as they become available by joining our Listserv. To join:
  1. Address an e-mail message to LISTSERV@LIST.NIH.GOV. No subject is necessary.
  2. In the body of the message, type SUBSCRIBE NHLBIINFO-L.
  3. A confirmation will be sent to you. When the confirmation is received, send a reply message and type OK in the body of the reply.

Also for Your Patients

The NHLBI Information Center offers a toll-free service (1-800-575-WELL) that features messages in Spanish or English about the prevention of high blood pressure and high blood cholesterol. The service allows callers to leave their name and address if they would like to receive additional information on these topics by mail.