# Appendix A - The DASH Diet

This eating plan is from the “Dietary Approaches to Stop Hypertension” (DASH) clinical study. The research was funded by the National Heart, Lung, and Blood Institute (NHLBI), with additional support by the National Center for Research Resources and the Office of Research on Minority Health, all units of the National Institutes of Health. The final results of the DASH study appear in the April 17, 1997, issue of the New England Journal of Medicine. The results show that the DASH “combination diet” lowered blood pressure and, so, may help prevent and control high blood pressure.

The “combination diet” is rich in fruits, vegetables, and low-fat dairy foods and low in saturated and total fat. It also is low in cholesterol; high in dietary fiber, potassium, calcium, and magnesium; and moderately high in protein.

The DASH eating plan shown below is based on 2,000 calories a day. Depending on your caloric needs, your number of daily servings in a food group may vary from those listed.

Food Group | Daily Servings | Serving Sizes | Examples and Notes | Significance of Each Food Group to the DASH Diet Pattern
Grains and grain products | 7–8 | 1 slice bread, 1/2 C dry cereal, 1/2 C cooked rice, pasta, or cereal | whole wheat bread, English muffin, pita bread, bagel, cereals, grits, oatmeal | major sources of energy and fiber
Vegetables | 4–5 | 1 C raw leafy vegetable, 1/2 C cooked vegetable, 6 oz vegetable juice | tomatoes, potatoes, carrots, peas, squash, broccoli, turnip greens, collards, kale, spinach, artichokes, beans, sweet potatoes | rich sources of potassium, magnesium, and fiber
Fruits | 4–5 | 6 oz fruit juice, 1 medium fruit, 1/4 C dried fruit, 1/4 C fresh, frozen, or canned fruit | apricots, bananas, dates, grapes, oranges, orange juice, grapefruit, grapefruit juice, mangoes, melons, peaches, pineapples, prunes, raisins, strawberries, tangerines | important sources of potassium, magnesium, and fiber
Low-fat or nonfat dairy foods | 2–3 | 8 oz milk, 1 C yogurt, 1.5 oz cheese | skim or 1% milk, skim or low-fat buttermilk, nonfat or low-fat yogurt, part-skim mozzarella cheese, nonfat cheese | major sources of calcium and protein
Meats, poultry, and fish | 2 or less | 3 oz cooked meats, poultry, or fish | select only lean; trim away visible fats; broil, roast, or boil, instead of frying; remove skin from poultry | rich sources of protein and magnesium
Nuts, seeds, and legumes | 4–5 per week | 1.5 oz or 1/3 C nuts, 1/2 oz or 2 Tbsp seeds, 1/2 C cooked legumes | almonds, filberts, mixed nuts, peanuts, walnuts, sunflower seeds, kidney beans, lentils | rich sources of energy, magnesium, potassium, protein, and fiber

[table image]