# Editors and Reviewers

## Editors

Jeffrey Beck

Dennis Benson

Janet Coleman

Marilu Hoeppner

Mark Johnson

Donna Maglott

Ilene Mizrachi

Rana Morris

Jim Ostell

Kim Pruitt

Wendy Rubinstein

Eric Sayers

Karl Sirotkin

Tatiana Tatusova

## Reviewers

Kathi Canese

Renata Geer

Sharmin Hussain

Evgeny Kireev

Adriana Malheiro

Karanjit Siyan

Bart Trawick

## Copy-editor

Stacy Lathrop

## Assignments

Section | Editor(s) / Reviewer(s)
Front Matter | Dennis Benson Janet Coleman Bart Trawick
Literature | Jeffrey Beck
Genomes | Kim Pruitt Tatiana Tatusova
Variation | Donna Maglott Adriana Malheiro
Health | Wendy Rubinstein
Genes and Gene Expression | Donna Maglott
Nucleotide | Ilene Mizrachi
Protein | Eric Sayers
Small Molecules and Biological Assays | Rana Morris Renata Geer
Tools | Kathi Canese Sharmin Hussain Mark Johnson Evgeny Kireev Karl Sirotkin Karanjit Siyan
Infrastructure | Karl Sirotkin
Metadata | Ilene Mizrachi
Book | Marilu Hoeppner Jim Ostell