# Tuberous sclerosis

Tuberous sclerosis is an hereditary disorder characterized by benign, tumor-like nodules of the brain and/or retinas, skin lesions, seizures and/or mental retardation. Patients may experience a few or all of the symptoms with varying degrees of severity.

Two genes for tuberous sclerosis have been found: TSC1 on chromosome 9, and TSC2 on chromosome 16. It took four years to pin down a specific gene from the TSC1 region of chromosome 9: in 1997, a promising candidate was found. Called hamartin by the discoverers, it is similar to a yeast protein of unknown function, and appears to act as a tumor suppressor: without TSC1, growth of cells proceeds in an unregulated fashion, resulting in tumor formation. TSC2 codes for a protein called tuberin, which, through database searches, was found to have a region of homology to a protein found in pathways that regulate the cell (GAP3, a GTPase-activation protein).

TSC1 has a homolog in yeast, which provides a system in which to model the human disease.

## Related diseases

- See other Cancers
- See other Diseases of the Nervous System

## Gene sequence

Genome view (http://www.ncbi.nlm.nih.gov/mapview/map_search.cgi?chr=hum_chr.inf&query=tuberous+sclerosis) see gene locations

Entrez Gene (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?cmd=PureSearch&db=gene&Cmd=DetailsSearch&Term=%22tuberous+sclerosis%22%5BAll+Fields%5D+AND+%22Homo+sapiens%22%5BOrganism%5D+AND+alive%5Bprop%5D) collection of gene-related information

BLink (http://www.ncbi.nlm.nih.gov/sutils/blink.cgi?pid=4507693&org=1) related sequences in different organisms

## The literature

Research articles (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=PubMed&details_term=tuberous+sclerosis%20AND%20%22pubmed%20pmc%22%5BFilter%5D) online full text

Books (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=books&details_term=tuberous sclerosis) online books section

OMIM catalog of human genes and disorders

GeneReviews a medical genetics resource

## Websites

CancerNet from the National Cancer Institute, NIH

Oncolink comprehensive cancer information from the University of Pennsylvania