# Rett syndrome

Rett syndrome (RTT) is a progressive neurodevelopmental disorder almost exclusively affecting females. With an incidence of about 1 in 10,000 births, it is a common cause of profound mental impairment in girls. Typically, babies with RTT develop normally until the age of 6 to 18 months, when their developmental milestones regress. They lose purposeful use of their hands and are seriously disabled for life, with reduced muscle tone and seizures. A temporary "autistic-like" phase often occurs at the onset of the disorder, and older children are known for their social engagement through intense eye gaze.

RTT is caused by mutations in the gene MeCP2, found on the X chromosome. MeCP2 is called a "transcriptional repressor" because it codes for a protein that controls the expression of other genes. Depending on what part of the gene contains the mutation, partial loss of this protein changes the environment experienced by developmentally important proteins which, in turn, leads to the RTT phenotype.

MeCP2 mutations seem to be more common in the X chromosome from sperm cells, which may explain why RTT is rare in boys, who do not inherit an X chromosome from their father. Girls, however, inherit one copy of the X chromosome from each parent. Girls with RTT have one functional copy of MeCP2 to counteract the mutated MeCP2 copy. But, in a normal process called X inactivation, one X chromosome is randomly inactivated in every cell. This results in the normal copy of MeCP2 being inactivated in some cells but not in others. X-inactivation coupled with the specific MeCP2 mutation type causes the range of symptoms seen in RTT. By studying the relationships between the MeCP2 proteins and the proteins affected by it, investigators hope to develop treatments for Rett syndrome.

## Related diseases

- See other Female-Specific Diseases
- See other Diseases of the Nervous System

## Gene sequence

Genome view (http://www.ncbi.nlm.nih.gov/mapview/map_search.cgi?chr=hum_chr.inf&query=rett) see gene locations

Entrez Gene collection of gene-related information

BLink (http://www.ncbi.nlm.nih.gov/sutils/blink.cgi?pid=4826830&org=1) related sequences in different organisms

## The literature

Research articles (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=PubMed&details_term=rett%20AND%20%22pubmed%20pmc%22%5BFilter%5D) online full text

Books (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=books&details_term=rett) online books section

OMIM catalog of human genes and disorders

GeneReviews a medical genetics resource

## Websites

Information Sheet (http://www.ninds.nih.gov/health_and_medical/disorders/rett_doc.htm) from the National Institute of Neurological Disorders and Stroke, NIH

International Rett Syndrome Association (http://www.rettsyndrome.org/) support and information for families