# Pendred syndrome

Pendred syndrome is an inherited disorder that accounts for as much as 10% of hereditary deafness. Patients usually also suffer from thyroid goiter. The recent discovery of the gene for Pendred syndrome illuminates a disorder that has confounded scientists for more than a century.

In December of 1997, scientists at NIH's National Human Genome Research Institute used the physical map of human chromosome 7 to help identify an altered gene, PDS, thought to cause pendred syndrome. The normal gene makes a protein, called pendrin, that is found at significant levels only in the thyroid and is closely related to a number of sulfate transporters. When the gene for this protein is mutated, the person carrying it will exhibit the symptoms of Pendred syndrome.

Because goiter is not always found in Pendred syndrome patients, it is possible that a defective pendrin gene will turn out to be responsible for some cases of deafness that had not previously been attributed to this disorder. The discovery of pendrin should also stimulate new angles of research into thyroid physiology and the role of altered sulfur transport in human disease.

## Related diseases

- See other Ear, Nose, and Throat Diseases
- See other Glands and Hormones Diseases

## Gene sequence

Genome view (http://www.ncbi.nlm.nih.gov/mapview/map_search.cgi?chr=hum_chr.inf&query=SLC26A4) see gene locations

Entrez Gene collection of gene-related information

BLink (http://www.ncbi.nlm.nih.gov/sutils/blink.cgi?pid=4505697&org=1) related sequences in different organisms

## The literature

Research articles (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=PubMed&details_term=pendred%20OR%20PDS%20AND%20%22pubmed%20pmc%22%5BFilter%5D) online full text

Books (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=books&details_term=pendred%20OR%20PDS) online books section

OMIM (http://www.ncbi.nlm.nih.gov/entrez/dispomim.cgi?id=274600) catalog of human genes and disorders

GeneReviews a medical genetics resource

## Websites

Research News (http://www.nhgri.nih.gov/NEWS/Pendred/) from the National Human Genome Research Institute, NIH