# Parkinson disease

Parkinson disease, first described by James Parkinson in 1817, is a growing national problem, with more than half a million Americans affected at any one time. Most people are over 50 years old when the disease appears, although it can occur in younger patients. It is a neurodegenerative disease that manifests as a tremor, muscular stiffness and difficulty with balance and walking. A classic pathological feature of the disease is the presence of an inclusion body, called the Lewy body, in many regions of the brain.

Until relatively recently, Parkinson disease was not though to be heritable, and research was primarily focused on environmental risk factors such as viral infection or neurotoxins. However, a positive family history was gradually perceived to be a risk factor, a view that was confirmed last year when a candidate gene for some cases of Parkinson disease was mapped to chromosome 4. Mutations in this gene have now been linked to several Parkinson disease families. The product of this gene, a protein called alpha-synuclein, is a familiar culprit: a fragment of it is a known constituent of Alzheimer disease plaques.

Since alpha-synuclein fragments are implicated in both Parkinson and Alzheimer diseases, there may be shared pathogenic mechanisms between the two, therefore research into one disease may aid understanding of the other. Further avenues for research are also being suggested by cross-species comparisons assisted by database searching. Among others, rats, cows and zebra finches all possess alpha-synuclein; in the rat they play a role in the sense of smell, while in the zebra finch it is thought to be involved in the process of song learning. Further work to elucidate the function of alpha-synuclein in humans, and therefore clues as to the pathology of Parkinson disease, should be assisted by studying these other species.

## Related diseases

- See other Diseases of the Nervous System

## Treatment

People with PD have more treatment choices than ever before, including: better and more varied dopaminergic drugs, >amantadine to treat dyskinesias, and deep brain stimulation (DBS) (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?cmd=PureSearch&db=pubmed&details_term=%22deep%20brain%20stimulation%22%5BAll%20Fields%5D%20AND%20%22parkinson%20disease%22%5BAll%20Fields%5D%20AND%20Clinical%20Trial%5Bptyp%5D) , that targets electrical stimulation in specific areas of brain tissue.

## Genetics

Several genesAlpha synuclein Leucine-rich repeat kinase 2 Parkin NR4A2 PARK7 PTEN induced putative kinase 1 All of the above (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?db=gene&cmd=Retrieve&list_uids=6622,5071,11315,120892,4929,65018) and neurotoxicants are now linked to PD, and research in both of these fields is progressing at a rapid pace.

## Trials

The NET-PD program (http://parkinsontrial.ninds.nih.gov/what-is-netpd.htm) has already facilitated the review of more than 100 drugs, and the NIH will be supporting a large Phase III clinical trial of creatine, the most promising drug examined to date.

Other NIH-supported trials involve the testing of the antioxidant coenzyme Q10, the fat molecule GM1 ganglioside, and the use of DBS in different brain regions - in order to identify the optimal brain target for stimulation.

## Websites

The Parkinson Web general information, with links to other Parkinson Disease Web sites.

MEDLINEplus (http://www.nlm.nih.gov/medlineplus/parkinsonsdisease.html) links on Parkinson disease compiled by the National Library of Medicine