# Marfan syndrome

Marfan syndrome is a connective tissue disorder, so affects many structures, including the skeleton, lungs, eyes, heart and blood vessels. The disease is characterized by unusually long limbs, and is believed to have affected Abraham Lincoln.

Marfan syndrome is an autosomal dominant disorder that has been linked to the FBN1 gene on chromosome 15. FBN1 encodes a protein called fibrillin, which is essential for the formation of elastic fibres found in connective tissue. Without the structural support provided by fibrillin, many tissues are weakened, which can have severe consequences, for example, ruptures in the walls of major arteries.

Beta blockers have been used to control some of the cardiovascular symptoms of Marfan syndrome; however, they are not effective against the skeletal and ocular problems, which can also be serious. A related disease has been found in mice, and it is hoped that the study of mouse fibrillin synthesis and secretion, and connective tissue formation, will further our understanding Marfan syndrome in humans.

The fibrillin protein

The fibrillin protein, mutated in Marfan syndrome, has about 60 domains, 47 of which bind calcium and have similarity to epidermal growth factor (EGF). In this figure, two of these domains are shown with one calcium ion associated with each domain.

To see the interactive version of this figure requires Cn3D (http://www.ncbi.nlm.nih.gov/Structure/CN3D/cn3d.shtml), a three-dimensional structure viewer.

## Related diseases

- See other Muscle and Bone Diseases
- See other Neonatal Diseases
- See other Skin and Connective Tissue Diseases

## Gene sequence

Genome view (http://www.ncbi.nlm.nih.gov/mapview/map_search.cgi?chr=hum_chr.inf&query=marfan) see gene locations

Entrez Gene collection of gene-related information

BLink (http://www.ncbi.nlm.nih.gov/sutils/blink.cgi?pid=4557591&org=1) related sequences in different organisms

## The literature

Research articles (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=PubMed&details_term=marfan%20AND%20%22pubmed%20pmc%22%5BFilter%5D) online full text

Books (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=books&details_term=marfan) online books section

OMIM catalog of human genes and disorders

GeneReviews a medical genetics resource

## Websites

National Marfan Foundation (http://www.marfan.org/) nonprofit organization