# Male pattern baldness

5-alpha reductase is an enzyme that was first discovered in the male prostate. Here it catalyzes the conversion of testosterone to dihydrotestosterone, which in turn binds to the androgen receptor and initiates development of the external genitalia and prostate. The gene for 5-alpha reductase has been mapped to chromosome 5.

More recently, 5-alpha reductase was found in human scalp and elsewhere in the skin, where it carries out the same reaction as in the prostate. It is thought that disturbances in 5-alpha reductase activity in skin cells might contribute to male pattern baldness, acne, or hirsutism. The discovery of a plant homolog of human 5-alpha reductase may lead to new drugs, and the race is now on to find inhibitors of 5-alpha reductase.

## Related diseases

- See other Male-Specific Diseases
- See other Skin and Connective Tissue Diseases

## Gene sequence

Genome view (http://www.ncbi.nlm.nih.gov/mapview/map_search.cgi?chr=hum_chr.inf&query=SRD5A1) see gene locations

Entrez Gene collection of gene-related information

BLink (http://www.ncbi.nlm.nih.gov/sutils/blink.cgi?pid=4507201&org=1) related sequences in different organisms

## The literature

Research articles (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=PubMed&details_term=5-alpha+reductase%20AND%20%22pubmed%20pmc%22%5BFilter%5D) online full text

Books (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=books&details_term=5-alpha+reductase) online books section

OMIM catalog of human genes and disorders