# Gyrate atrophy of the choroid and retina

People suffering from gyrate atrophy of the choroid (the thin coating of the eye) and retina face a progressive loss of vision, with total blindness usually occurring between the ages of 40 and 60. The disease is an inborn error of metabolism.

The gene whose mutation causes gyrate atrophy is found on chromosome 10, and encodes an enzyme called ornithine ketoacid aminotransferase (OAT). Different inherited mutations in OAT cause differences in the severity of symptoms of the disease. OAT converts the amino acid ornithine from the urea cycle ultimately into glutamate. In gyrate atrophy, where OAT function is affected, there is an increase in plasma levels of ornithine.

It is already known that reduction of the amino acid arginine in the diet has a salutary effect on most patients. Current lines of research into the disease include: (1) investigating how variant mutations of the alleles (versions of the gene inherited) interact in order to cause the differing symptoms of the disease and (2) work on mouse models of the disease is furthering our understanding, which is hoped will lead to a true cure.

## Related diseases

- See other Diseases of the Eye

## Gene sequence

Genome view (http://www.ncbi.nlm.nih.gov/mapview/map_search.cgi?chr=hum_chr.inf&query=gyrate+atrophy) see gene locations

Entrez Gene collection of gene-related information

BLink (http://www.ncbi.nlm.nih.gov/sutils/blink.cgi?pid=4557809&org=1) related sequences in different organisms

## The literature

Research articles (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=PubMed&details_term=gyrate+atrophy%20AND%20%22pubmed%20pmc%22%5BFilter%5D) online full text

Books (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=books&details_term=gyrate+atrophy) online books section

OMIM catalog of human genes and disorders

## Websites

Eye News Online (http://www.eye-news.com/vol3_6.dir/review/16rev3_5l.htm) containing information on gyrate atrophy

The National Eye Institute (http://www.nei.nih.gov/) research and information