# Essential tremor

Tremor, or uncontrollable shaking, is a common symptom of neurological disorders such as Parkinson disease, head trauma, and stroke. However, many people with tremor have what is called idiopathic or essential tremor. In these cases, which number 3-4 million people in the US, the tremor itself is the only symptom of the disorder. While essential tremor may involve other parts of the body, the hands and head are most often affected.

In more than half of the cases, essential tremor is inherited as an autosomal dominant trait, which means that children of an affected individual will have a 50% chance of also developing the disorder. In 1997, the ETM1 gene (also called FET1) was mapped to chromosome 3 in a study of Icelandic families, while another gene, called ETM2, was mapped to chromosome 2 in a large American family of Czech descent. That two genes for essential tremor have been found on two different chromosomes demonstrates that mutations in a variety of genes may lead to essential tremor.

While the mainstays of treatment are drugs such as propranolol and primidone, alternative drugs and surgical treatments are also available. Further understanding of the molecular mechanism behind the disease awaits the discovery and cloning of an essential tremor gene.

## Related diseases

- See other Diseases of the Nervous System

## Gene sequence

Genome view (http://www.ncbi.nlm.nih.gov/mapview/map_search.cgi?chr=hum_chr.inf&query=tremor) see gene locations

Entrez Gene collection of gene-related information

## The literature

Research articles (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=PubMed&details_term=tremor%20AND%20%22pubmed%20pmc%22%5BFilter%5D) online full text

Books (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=books&details_term=tremor) online books section

OMIM (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=omim&details_term=tremor) catalog of human genes and disorders

## Websites

Factsheet (http://www.ninds.nih.gov/health_and_medical/disorders/tremor_doc.htm) from the National Institute of Neurological Disorders and Stroke, NIH

Information (http://www.essentialtremor.org/) from the Essential Tremor Foundation