# Ellis-van Creveld syndrome

Ellis-van Creveld syndrome, also known as "chondroectodermal dysplasia," is a rare genetic disorder characterized by short-limb dwarfism, polydactyly (additional fingers or toes), malformation of the bones of the wrist, dystrophy of the fingernails, partial hare-lip, cardiac malformation, and often prenatal eruption of the teeth.

The gene causing Ellis-van Creveld syndrome, EVC, has been mapped to the short arm of chromosome 4. As yet, the function of a healthy EVC gene is not known; this is one of the most important questions that must be answered about the disease, since it would give an indication as to the molecular mechanism of the disease.

Ellis-van Creveld syndrome is often seen among the Old Order Amish community in Lancaster County, Pennsylvania. Because this group of people is small and isolated, it affords a rare opportunity to observe the passage of this particular disorder from generation to generation. A pattern of inheritance can be observed that has indicated the disease is autosomal-recessive (i.e. a mutated gene form both parents is required before the effects of the disease to become apparent).

## Related diseases

- See other Muscle and Bone Diseases
- See other Skin and Connective Tissue Diseases

## Gene sequence

Genome view (http://www.ncbi.nlm.nih.gov/mapview/map_search.cgi?chr=hum_chr.inf&query=EVC) see gene locations

Entrez Gene collection of gene-related information

BLink (http://www.ncbi.nlm.nih.gov/sutils/blink.cgi?pid=7657073&org=1) related sequences in different organisms

## The literature

Research articles (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=PubMed&details_term=EVC%20AND%20%22pubmed%20pmc%22%5BFilter%5D) online full text

Books (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=books&details_term=EVC) online books section

OMIM catalog of human genes and disorders