# Diastrophic dysplasia

Diastrophic dysplasia (DTD) is a rare growth disorder in which patients are usually short, have club feet, and have malformed handsmand joints. Although found in all populations, it is particularly prevalent in Finland.

The gene whose mutation results in DTD maps to chromosome 5 and encodes a novel sulfate transporter. This ties in with the observation of unusual concentrations of sulfate in various tissues of DTD patients. Sulfate is important for skeletal joints because cartilage—the shock-absorber of joints—requires sulfur during its manufacture. Adding sulfur increases the negative charge within cartilage, which contributes to its shock-absorbing properties.

A great deal of further research must be done before this condition is fully understood and effective therapies are developed.

## Related diseases

- See other Glands and Hormones Diseases
- See other Muscle and Bone Diseases
- See other Skin and Connective Tissue Diseases

## Gene sequence

Genome view (http://www.ncbi.nlm.nih.gov/mapview/map_search.cgi?chr=hum_chr.inf&query=DTD) see gene locations

Entrez Gene collection of gene-related information

BLink (http://www.ncbi.nlm.nih.gov/sutils/blink.cgi?pid=4557539&org=1) related sequences in different organisms

## The literature

Research articles (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=PubMed&details_term=diastrophic%20dysplasia%20AND%20%22pubmed%20pmc%22%5BFilter%5D) online full text

Books (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=books&details_term=diastrophic%20dysplasia) online books section

OMIM catalog of human genes and disorders

GeneReviews a medical genetics resource