# Deafness

Hearing loss is extremely common and can present at any time from infancy to old age. About 1 in 1000 infants has profound hearing impairment, with half thought to be of genetic origin. Many deafness genes exist, but the most common cause of hearing loss in American and European populations is a mutation in the connexin 26 (Cx26) gene. Cx26 has a carrier rate of 3%, similar to that for cystic fibrosis, and it causes about 20% of childhood deafness.

Mutations in Cx26 cause congenital syndromic and nonsyndromic deafness—that is, the deafness is not accompanied by other symptoms, such as blindness. Cx26 is located on chromosome 13q11-12 and codes for a gap junction protein called connexin 26. Gap junctions are plasma membrane channels that allow the movement of small molecules and ions between adjacent cells. Gap junctions of the inner ear may play a role in maintaining potassium homeostasis, which is important for inner-ear function and, thus, hearing. It has been proposed that mutations in Cx26 may disrupt potassium circulation and result in deafness.

Connexin 26

Connexin 26 (GJB2) is one of the main proteins involved in potassium (K+) homeostasis in the cochlea of the inner ear. It is found in the supporting cells, fibrocytes of the spiral ligament and in cells of the spiral limbus

Adapted from Steel, K.P. (1999) Science 285, 1363-1364, with permission.

The discovery that Cx26 mutations are a cause of congenital hearing loss can help in the early diagnosis of hearing impairment. Early identification and management of deafness is important for the development of language and social skills.

## Related diseases

- See other Ear, Nose, and Throat Diseases
- See other Diseases of the Nervous System

## The Genes

Genome Data Viewer: (https://www.ncbi.nlm.nih.gov/genome/gdv/browser/gene/?id=2706) GJB2 gene

Entrez Gene collection of gene-related information

## The Diseases

GeneReviews a medical genetics resource

Research articles (https://pubmed.ncbi.nlm.nih.gov/?term=%28%22Nonsyndromic+hearing+loss+and+deafness%22%5BAll+Fields%5D+OR+DFNB1%5BAll+Fields%5D%29+AND+free+full+text%5Bsb%5D) online full text

OMIM (https://www.ncbi.nlm.nih.gov/omim?LinkName=gene_omim&from_uid=2706) catalog of human genes and disorders

## Websites

NIDCD (http://www.nidcd.nih.gov/) National Institute on Deafness and Other Communication Disorders

Info to Go (https://clerccenter.gallaudet.edu/national-resources/info/) from Gallaudet University

MEDLINEplus (http://www.nlm.nih.gov/medlineplus/hearingdisordersdeafness.html) from the National Library of Medicine