# Colon cancer

The American Cancer Society estimates that there will be 93,800 new cases of colon cancer diagnosed in the US in 2000, with 47,700 resulting deaths. All kinds of cancer occur when cell division, normally a very highly regulated process, gets out of control. While environmental factors can certainly contribute to a person's risk of cancer (e.g. smoking, diet, and exercise), most cancers have a genetic basis too. Literally hundreds of genes and proteins are involved in monitoring the process of cell division and DNA replication; a mutation in one or more of these genes or proteins can sometimes lead to uncontrolled cancerous growth.

Colon cancer is one of the most common inherited cancer syndromes known. Among the genes found to be involved in colorectal cancer are: MSH2 and MSH6 both on chromosome 2 and MLH1, on chromosome 3. Normally, the protein products of these genes help to repair mistakes made in DNA replication. If the MSH2, MSH6, and MLH1 proteins are mutated and therefore don't work properly, the replication mistakes are not repaired, leading to damaged DNA and, in this case, colon cancer.

It is not clear why mutations in genes that are essential in all tissues preferentially cause cancer in the colon. However, studies on the equivalent genes in mice and brewer's yeast are helping to further our understanding of the mechanisms of DNA repair and the role that environmental factors might play in colon cancer incidence.

## Related diseases

- See other Cancers
- See other Diseases of the Digestive System

## Gene sequence

Genome view (http://www.ncbi.nlm.nih.gov/mapview/map_search.cgi?chr=hum_chr.inf&query=MSH2%20OR%20MSH6%20OR%20MLH1) see gene locations

Entrez Gene (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?cmd=PureSearch&db=gene&details_term=%28%28%28%28MSH2%5BGene%20Name%5D%20OR%20MSH6%5BGene%20Name%5D%29%20OR%20MLH1%5BGene%20Name%5D%29%20AND%20alive%5Bprop%5D%29%20AND%20%22Homo%20sapiens%22%5BOrganism%5D%29) collection of gene-related information

BLink (http://www.ncbi.nlm.nih.gov/sutils/blink.cgi?pid=4557761&org=1) related sequences in different organisms

## The literature

Research articles (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=PubMed&details_term=colon%20cancer%20AND%20%22pubmed%20pmc%22%5BFilter%5D) online full text

Books (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=books&details_term=colon%20cancer) online books section

OMIM (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=omim&details_term=colon%20cancer) catalog of human genes and disorders

## Websites

CancerNet from the National Cancer Institute, NIH

American Cancer Society (http://www.cancer.org) research and patient support

Oncolink comprehensive cancer information from the University of Pennsylvania