# Burkitt lymphoma

Burkitt lymphoma is a rare form of cancer predominantly affecting young children in Central Africa, but the disease has also been reported in other areas. The form seen in Africa seems to be associated with infection by the Epstein-Barr virus, although the pathogenic mechanism is unclear.

Burkitt lymphoma results from chromosome translocations that involve the Myc gene. A chromosome translocation means that a chromosome is broken, which allows it to associate with parts of other chromosomes. The classic chromosome translocation in Burkitt lymophoma involves chromosome 8, the site of the Myc gene. This changes the pattern of Myc's expression, thereby disrupting its usual function in controlling cell growth and proliferation.

We are still not sure what causes chromosome translocation. However, research in model organisms such as mice is leading us toward a better understanding of how translocations occur and, hopefully, how this process contributes to Burkitt lymphoma and other cancers such as leukemia.

## Related diseases

- See other Blood and Lymph Diseases
- See other Cancers
- See other Diseases of the Immune System

## Gene sequence

Genome view (http://www.ncbi.nlm.nih.gov/mapview/map_search.cgi?chr=hum_chr.inf&query=myc) see gene locations

Entrez Gene collection of gene-related information

BLink (http://www.ncbi.nlm.nih.gov/sutils/blink.cgi?pid=12962935&org=1) related sequences in different organisms

## The literature

Research articles (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?cmd=PureSearch&db=PubMed&details_term=burkitt%20AND%20%22pubmed%20pmc%22%5BFilter%5D) online full text

Books (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?cmd=PureSearch&db=books&details_term=burkitt) online books section

OMIM catalog of human genes and disorders

## Websites

CancerNet from the National Cancer Institute, NIH

American Cancer Society (http://www.cancer.org/) research and patient support

Oncolink (https://www.oncolink.org/) comprehensive cancer information from the University of Pennsylvania