# Atherosclerosis

Atherosclerosis is a disease that can affect people at any age, although it usually doesn't pose a threat until people reach their forties or fifties. It is characterized by a narrowing of the arteries caused by cholesterol-rich plaques of immune system cells. Key risk factors for atherosclerosis, which can be genetic and/or environmental, include: elevated levels of cholesterol and triglyceride in the blood, high blood pressure, and cigarette smoke.

A protein called apolipoprotein E, which can exist in several different forms, is coded for by a gene found on chromosome 19. It is important for removing excess cholesterol from the blood, and does so by carrying cholesterol to receptors on the surface of liver cells. Defects in apolipoprotein E sometimes result in its inability to bind to the receptors, which leads to an increase a person's blood cholesterol and consequently their risk of atherosclerosis.

Currently, a debate is raging over how the various mutated forms of apolipoprotein E affect the body. As a result, many of the treatments proposed remain in their experimental phase. While mice are proving useful for modeling the human disease, a great deal of research is still required before we can fully understand the mechanisms that regulate the levels of lipoproteins—like apolipoprotein E—in the blood.

## Related diseases

- See other Diseases of the Heart and Blood Vessels

## Gene sequence

Genome view (http://www.ncbi.nlm.nih.gov/mapview/map_search.cgi?chr=hum_chr.inf&query=APOE) see gene locations

Entrez Gene collection of gene-related information

BLink (http://www.ncbi.nlm.nih.gov/sutils/blink.cgi?pid=4557325&org=1) related sequences in different organisms

## The literature

Research articles (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=PubMed&details_term=atherosclerosis%20AND%20%22pubmed%20pmc%22%5BFilter%5D) online full text

Books (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=books&details_term=atherosclerosis) online books section

OMIM catalog of human genes and disorders

## Websites

National Heart, Blood and Lung Institute (http://www.nhlbi.nih.gov/health/public/heart/index.htm) cardiovascular information

American Heart Association information on heart disease and stroke