# Ataxia telangiectasia

The first signs of ataxia telangiectasia (A-T) usually appear in the second year of life as a lack of balance and slurred speech. It is a progressive, degenerative disease characterized by cerebellar degeneration, immunodeficiency, radiosensitivity (sensitivity to radiant energy, such as x-ray), and a predisposition to cancer.

Back in 1988 the gene responsible for A-T was mapped to chromosome 11. The subsequent identification of the gene proved difficult; it was 7 more years until the human ATM gene was cloned. The diverse symptoms seen in A-T reflect the main role of ATM, which is to induce several cellular responses to DNA damage. When the ATM gene is mutated, these signaling networks are impaired, and so the cell does not respond correctly to minimize the damage.

The ATM protein

The ATM protein mediates responses to DNA damage, in particular those that control progression through the cell cycle.

Some of the ATM-dependent signaling pathways are found in yeast. Because these pathways appear to be conserved throughout evolution, they are likely to be central to the DNA damage response. Research into finding an effective therapy for A-T sufferers is likely to be helped by harnessing the power of yeast genetics, which allows more rapid and systematic study of the pathways affected by an ATM mutation.

## Related diseases

- See other Diseases of the Heart and Blood Vessels
- See other Diseases of the Immune System
- See other Diseases of the Nervous System

## The Genes

Genome Data Viewer: (https://www.ncbi.nlm.nih.gov/genome/gdv/browser/gene/?id=472) ATM gene

Entrez Gene collection of gene-related information

## The Diseases

GeneReviews a medical genetics resource

Research articles (https://pubmed.ncbi.nlm.nih.gov/?term=ataxia+telangiectasia%5BAll+Fields%5D+AND+free+full+text%5Bsb%5D) online full text

OMIM catalog of human genes and disorders

MEDLINEplus (http://www.nlm.nih.gov/medlineplus/ataxiatelangiectasia.html) Medical encyclopedia from the National Library of Medicine, NIH

## Websites

Patient information (http://www.ninds.nih.gov/disorders/a_t/a-t.htm) from the National Institute of Neurological Disorders and Stroke, NIH