# Alzheimer disease

Alzheimer disease (AD) is the fourth leading cause of death in adults. The incidence of the disease rises steeply with age. AD is twice as common in women than in men, although former president Ronald Reagan is a well known disease sufferer. Some of the most frequently observed symptoms of the disease include a progressive inability to remember facts and events and, later, to recognize friends and family.

AD tends to run in families; currently, mutations in four genes, situated on chromosomes 1, 14, 19, and 21, are believed to play a role in the disease. The best-characterized of these are PS1 (or AD3) on chromosome 14 and PS2 (or AD4) on chromosome 1. The formation of lesions made of fragmented brain cells surrounded by amyloid-family proteins are characteristic of the disease. Interestingly, these lesions and their associated proteins are closely related to similar structures found in Down Syndrome. Tangles of filaments largely made up of a protein associated with the cytoskeleton have also been observed in samples taken from Alzheimer brain tissue.

Currently, scientists are studying the interrelationship between the various gene loci (particularly the mutation on chromosome 21) and how environmental factors could effect a person's susceptibility to AD. Recently, use of a mouse model of the disease identified an enzyme that may be responsible for the increase in amyloid production characteristic of AD. If a way to regulate this enzyme could be found, then AD may be slowed or halted in some people.

## Related diseases

- See other Diseases of the Nervous System

## Gene sequence

Genome view (http://www.ncbi.nlm.nih.gov/mapview/map_search.cgi?chr=hum_chr.inf&query=alzheimer) see gene locations

Entrez Gene (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?cmd=PureSearch&db=gene&details_term=%28%28alzheimer%5BDisease%20or%20phenotype%5D%20AND%20alive%5Bprop%5D%29%20AND%20%22Homo%20sapiens%22%5BOrganism%5D%29) collection of gene-related information

BLink (http://www.ncbi.nlm.nih.gov/sutils/blink.cgi?pid=4506163&org=1) related sequences in different organisms

## The literature

Research articles (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=PubMed&details_term=alzheimer%20AND%20%22pubmed%20pmc%22%5BFilter%5D) online full text

Books (http://www.ncbi.nlm.nih.gov:80/entrez/query.fcgi?cmd=PureSearch&db=books&details_term=alzheimer) online books section

OMIM catalog of human genes and disorders

GeneReviews a medical genetics resource

## Websites

Alzheimer's Association (http://www.alz.org/) or call 1-800-272-3900

Alzheimer's Disease Education and Referral Center (http://www.alzheimers.org/) a service of the National Institute on Aging, National Institutes of Health

MEDLINEplus (http://www.nlm.nih.gov/medlineplus/alzheimersdisease.html) links on Alzheimer's disease compiled by the National Library of Medicine