# Diseases of the Eye

The function of our eyes is to allow us to see the objects in our surroundings at variable distances and under various conditions of lights. This function is achieved by a very complex arrangement of layers and structures found in the eye. In addition, two pockets of transparent fluid — the aqueous and vitreous humors — nourish eye tissues and help maintain constant eye shape.

The eye is comprised of three layers: an outer protective white coating called the sclera; a middle layer (choroid) containing blood vessels which nourish the eye; and an inner layer (retina) which contains the nerves that bear information to the brain for processing.

The cornea is the clear portion found at the front of the eye and serves to bend light rays. The iris, an extension of the choroid, is the colored portion of the eye and is made up of a spongy tissue. The pupil (black) is an opening in the iris that allows light into the eye. The lens then helps focus the light rays onto photoreceptors, which absorb and convert the light into electrical signals that carry information. The optic nerve contains fibers that transmit these signals to the brain for interpretation of the objects seen.

With the recent advances in molecular genetic techniques, new genes that cause eye disease are rapidly being identified, such as for those diseases discussed here. In many instances, these findings allow researchers to develop innovative strategies for preventing or slowing the progress of genetic eye diseases.

## Diseases

- Best disease
- Glaucoma
- Gyrate atrophy of the choroid and retina
- Retinoblastoma

## Did you know ...?

Everyone has a blind spot, to find yours, do this test (you can use the mouse cursor instead of a pencil)...