# VKORC1 Gene Polymorphisms and Response to Warfarin Therapy

## Background

Warfarin inhibits Vitamin K epoxide reductase (VKOR), an enzyme complex that facilitates recycling reduced Vitamin K through its interaction with subunit protein 1 (VKORC1). Rare mutations in the VKORC1 gene that lead to amino acid changes in the protein product have been found in familial cases of patients with both a deficiency of Vitamin-K-dependent clotting factors type 2 (online Mendelian inheritance in man, OMIM, #607473) and resistance to coumarin-type anticoagulant drugs (OMIM #122700).49,50 These rare mutations are unlikely to explain the large variability in patient response to warfarin at the population level. However, the common non-coding variants of the VKORC1 gene may explain part of the variability in warfarin sensitivity and dose requirements at the population level.51–53 To date, several common variants of VKORC1 have been studied for their effects on response to warfarin.

Apart from VKORC1 gene polymorphisms, common variants of the gene encoding the CYP2C9 enzyme (belonging to the cytochrome P450 family) do influence warfarin maintenance dose requirements.12,14 We performed a systematic review to evaluate the effects of common VKORC1 variants on warfarin maintenance dose and measurements of anticoagulation status.

### Data Synthesis and Analysis for an Association between the VKORC1 Gene Variant and Warfarin Therapy

We evaluated all common VKORC1 variants that had at least 5% frequency among unrelated patients in at least one study. For all identified common VKORC1 genetic variations and their relationship with eligible outcomes, we recorded whether the association was statistically significant at the 0.05 level and the direction of the association. We evaluated both qualitative and quantitative data on potential associations. We performed meta-analyses whenever four or more studies had available data on the same outcome and the same polymorphism. Therefore, we performed meta-analyses only for the differences in the maintenance dose across VKORC1 genotypes for 3 SNPs: rs9934438 (g.6484C>T or c.1173C>T), rs7294 (g.9041G>A or c.3730G>A), and rs8050894 (g.6853G>C or c.1542G>C). Two of these SNPs (namely rs9934438 and rs7294) are in strong linkage disequilibrium between them; in addition, the third SNP (rs7294) as well as at least 2 other SNPs (namely rs9923231 [g.3673G>A or c.-1639G>A] and rs2359612 [g.7566T>C or c.2255T>C]) are also in linkage disequilibrium between them and with the first two. This means that the alleles of these SNPs tend to be inherited together. For this reason all analyses across these SNPs are stochastically dependent (correlated).

We assumed dominant or recessive inheritance by combining the average maintenance doses for the proper genotypic groups in each study and also compared the results with those of homozygotes. We used an exact test to evaluate deviations from the HWE-predicted proportions in each study and per ethnic descent stratum when applicable.54 We tested for deviations from HWE across studies and their similarity across studies using exact tests.55

Subgroup analyses by ethnic descent (European, Asian, and African American) were performed. In sensitivity analyses, we excluded studies in which the genotype proportions deviated significantly from the HWE-predicted proportions and studies for which means and standard deviations were approximated from medians or ranges.15

## Results

From 288 citations, 28 full-text articles were reviewed; 18 studies20,29,30,36,39,51,52,56–66 reported data on the association of common VKORC1 genetic variations (all were SNPs) and outcomes of interest.

### Description of studies

Nineteen studies evaluating 21 VKORC1 SNPs contained information on 23 racial descent strata; European descent patients (14 strata), Asian descent patients (7 strata), and African American descent patients (2 strata) (Figure 2.1). All studies recruited warfarin-treated patients from anticoagulation clinics. The therapeutic INR target was between 2 and 3 in the majority of studies. About 50 percent of the studies enrolled only patients with stabilized maintenance doses, and the remaining studies included patients during the induction phase.

Nine studies were prospective (Table 2.1). Mean ages of warfarin-treated patients ranged from 43 to 72 years. More than one-half of the participants were male. Only one of 18 studies reported that the personnel who did the genotyping were blinded to the laboratory or clinical data of the patients, and only three studies clearly reported quality control of the reliability and reproducibility of genotyping.

Table 2.1 Characteristics of Studies Testing the Association between the VKORC1 Genotype and Response to Warfarin Therapy

Characteristics | Description: number of studies (references)
Total | 19 studies20,29,30,36,39,43,51,52,56–66
Study design | Prospective cohort: 9^29,30,36,39,57,59,61,62,66^ Retrospective cohort: 9^51,52,56,58,60,63–65,67^ RCT: 1^43^
Ethnicity | Caucasians: 8^51,52,57,59,60,64,65,67^ Asians: 5^29,30,39,58,66^ Mixed: 4^36,56,61,63^ Not documented: 2^43,62^
Setting | Anticoagulation clinic: 14^20,39,51,52,56,57,59–66^ Other: 4^29,30,43,58^ Not documented: 1^36^
Beginning of patient recruitment | Warfarin initiation phase: 5^43,51,58,61,68^ Warfarin maintenance phase: 9 Not documented: 5^29,39,52,59,60^
Commonly examined SNPs | rs9934438 (g.6484C>T): 13^29,30,36,51,52,57–61,66–68^ rs7294 (g.9041G>A): 11^36,39,51,52,58–60,63,66–68^ rs8050894 (g.6853G>C): 7^29,30,39,51,59,64,66^

RCT: randomized controlled trial; SNP: single nucleotide polymorphism

### Overview of the reported associations

Eighteen studies evaluating 21 VKORC1 SNPs identified associations between SNPs and mean warfarin maintenance dose or other anticoagulation variables. No study reported associations between VKORC1 SNPs and bleeding outcomes. The most commonly examined association was between three SNPs [rs9934438 (g.6484C>T), rs7294 (g.9041G>A), and rs8050894 (g.6853G>C)] and the mean maintenance warfarin dose (Table 2 in Appendix 2, Figure 2.1).

In the individual studies, most associations were described as statistically significant (red and blue cells in the figure). Studies agreed in the direction and statistical significance of associations between genetic effects for all SNPs and the outcome.

Figure 2.1 Evidence map of associations between VKORC1 single nucleotide polymorphisms with mean warfarin maintenance dose or anticoagulation outcomes by genetic descent strata. Numbers 1 through 23 under each outcome identify the specific genetic descent strata: see the key below the table

Dt: Time (to stable dose); INR: International normalized ratio; mean dose: mean maintenance dose. “Minor allele” is the less frequent of the two alleles in the population. We coined the genetic comparisons by considering as “variant allele” the allele with the lowest frequency (i.e., the minor allele) in European descent populations, to ensure correct representation of the direction of the genetic effects. The color code of each cell is based on what is reported by each study. Statistical significance status in the primary studies could be based on different analyses (e.g. haplotype-based analyses or adjusted analyses) than the ones we performed in this technology assessment.

Key to the genetic descent strata and studies summarized in Figure 2.1
Order in figure | Author | Year | Descent | Reference
1 | Aquilante | 2006 | European | 56
2 | Carlquist | 2006 | European | 57
3 | D'Andrea | 2005 | European | 52
4 | Herman | 2006 | European | 20
5 | Li | 2006 | European | 59
6 | Osman | 2006 | European | 60
7 | Rieder | 2005 | European | 51
8 | Schelleman [Eur] | 2007 | European | 61
9 | Sconce | 2005 | European | 62
10 | Takahashi [Eur] | 2006 | European | 36
11 | Tham [Indian] | 2006 | European | 63
12 | Vecsler | 2006 | European | 64
13 | Veenstra | 2005 | European | 39
14 | Wadelius | 2005 | European | 65
15 | Kimura | 2007 | Asian | 58
16 | Mushiroda | 2006 | Asian | 29
17 | Obayashi | 2006 | Asian | 30
18 | Takahashi [As] | 2006 | Asian | 36
19 | Tham [Chinese] | 2006 | Asian | 63
20 | Tham [Malay] | 2006 | Asian | 63
21 | Yuan | 2005 | Asian | 66
22 | Schelleman [Afr] | 2007 | African American | 61
23 | Takahashi [Afr] | 2006 | African American | 36

Key to the nomenclature of the SNPs that are mentioned in the report above
rsNo | snp_c | snp_g
- | c.1196G>A | -
- | c.129C>T | -
- | c.1331G>A | -
- | c.1338G>A | -
- | c.343G>A | -
- | c.3462C>T | -
- | c.523G>A | -
- | c.837T>C | -
- | - | g.2653G>C
- | - | g.381T>C
- | - | g.7566T>C
rs11150606 | - | g.7040A>G
rs17708472 | c.689C>T | g.6009C>T
rs17878259 | - | g.4719T>C
rs17880887 | c.-4451G>T | g.861G>T
rs2359612 | c.2255T>C | g.7566T>C
rs2884737 | c.497T>G | g.5808A>C
rs7294 | c.3730G>A | g.9041G>A
rs8050894 | c.1542G>C | g.6853G>C
rs9923231 | c.-1639G>A | g.3673G>A
rs9934438 | c.1173C>T | g.6484C>T

#### Key Question #1a Among patients taking warfarin, is there any association between carrying the genotype and clinical variables, such as the effective dose of warfarin?

##### VKORC1 rs9934438 (g.6484C>T or c.1173C>T)

###### Association between VKORC1 rs9934438 (g.6484C>T or c.1173C>T) and mean warfarin maintenance dose

Thirteen studies examined the association between VKORC1 rs9934438 (g.6484C>T or c.1173C>T) and mean warfarin maintenance dose in 17 ethnic-descent strata (10 in European descent, 5 in Asian descent, and 2 in African American descent) (Table 2 in Appendix 2). Data for meta-analyses were available in eight studies of 13 studies totaling 1,873 patients20,29,30,36,57–59,61 (5 European-descent strata, 4 Asian-descent strata, and 1 African American stratum). Five studies reporting seven ethnic descent strata (not included in the meta-analysis) reported estimates similar to that of the meta-analysis (Figure 2.1).

In three of the 10 strata, the genotype distribution deviated significantly from the HWE-predicted proportions (European descent in Herman 2006^67^ and Schelleman 2005^61^ and Asian descent in Takahashi 2005^36^; exact P value <0.03 in all three cases). Standard deviations of warfarin maintenance doses were imputed in six of 10 ethnic descent strata described in four studies.29,36,59,61

Overall, among 1,748 patients and under a dominant genetic model, the mean maintenance dose among carriers of the T allele was lower than it was in CC homozygotes (Figure 2.2, panel A), without between-strata heterogeneity. Under a recessive model and 1,804 patients, TT homozygotes had lower maintenance doses than did those with CT or CC genotypes (Figure 2.2, panel B), although with substantial and significant heterogeneity. Among 1,123 patients with TT genotypes also had lower mean maintenance doses than did CC homozygotes (Figure 2.2, panel C), without statistical heterogeneity across strata. These findings suggest an additive genetic effect for the T allele of rs9934438.

No single subgroup explains the observed between-strata heterogeneity across all three genotype comparisons (Table 2.2). However, the mean differences in the average maintenance dose in all analyses consistently suggest that carriers of T allele have lower dose requirements.

Figure 2.2 Individual and pooled estimates for an association between VKORC1 rs9934438 and mean warfarin maintenance dose

A) Dominant model for rs9934438 (CT+TT vs. CC), B) Recessive model for rs9934438 (TT vs. CT+CC), and c) Extreme homozygotes for rs9934438 (TT vs. CC)

X-axis indicates Mean diff: mean difference in the average daily maintenance dose of warfarin (in mg).

Obayashi and Kimura had 1 and 0 CC homozygotes and therefore are not included in panels A and C. The African American stratum of Shelleman had 1 TT homozygote and therefore is not included in panels B and C.

Overall, when the pooled effect sizes are considered, results are consistent with an additive genetic model.

Table 2.2 Subgroup Comparisons on the Genetic Effects of rs9934438 on Mean Warfarin Maintenance Dose

Study or summary | Dominant model (CT +TT vs. CC)^*^ | | | Recessive model (TT vs. CT+CC)^*^ | | | Extreme homozygotes (TT vs. CC)^*^
Study or summary
Study or summary | N (patients) | Mean difference, mg/d (95% CI) | P_Het_ (I^2^ [%]) | N (patients) | Mean difference, mg/d (95% CI) | P_Het_ (I^2^ [%]) | N (patients) | Mean difference, mg/d (95% CI) | P_Het_ (I^2^ [%])
All studies | 8 (1748) | −2.16 (−2.56, −1.76) | 0.24 (24) | 9 (1804) | − 1.84 (−2.38, −1.30) | <0.01 (86) | 7 (1123) | −3.08 (−3.58, −2.58) | 0.13 (40)
Racial descent
European | 5 (696) | −2.16 (−2.64, −1.67) | 0.15 (41) | 5 (696) | −2.29 (−2.75, −1.83) | 0.08 (53) | 5 (373) | −3.17 (−3.70, −2.64) | 0.15 (41)
Asian | 2 (890) | −2.51 (−2.64, 1.67) | 0.16 (49) | 4 (1108) | −1.25 (−1.78, 0.73) | 0.03 (67) | 2 (750) | −2.74 (−4.40, −1.09) | 0.13 (56)
African American | 1 (162) | −1.83 (−3.55, 1.08) | NA | 0 (0) | NA | NA | 0 (0) | NA | NA
Only patients with stable dose
Yes | 4 (510) | −2.32 (−3.05, −1.59) | 0.03 (66) | 5 (635) | −2.15 (−2.84, −1.47) | <0.01 (80) | 4 (301) | −3.34 (−4.04, −2.64) | 0.09 (53)
No | 4 (1238) | −2.08 (−2.71, −1.44) | 0.93 (0) | 4 (1169) | −1.40 (−1.98, −0.81) | 0.02 (71) | 3 (822) | −2.69 (−3.35, −2.03) | 0.50 (0)
Prospective study
Yes | 7 (1583) | −1.93 (−2.30, −1.57) | 0.50 (0) | 7 (1546) | −1.88 (−2.50, −1.26) | <0.01 (83) | 6 (1023) | −2.94 (−3.49, −2.39) | 0.19 (33)
No | 1 (165) | −2.73 (−3.43, −2.02) | NA | 2 (258) | −1.68 (−3.22, −0.13) | <0.01 (94) | 1 (100) | −3.59 (−4.31, −2.87) | NA
Deviation from HWE
Yes | 3 (382) | −2.71 (−3.30, −2.14) | 0.62 (0) | 3 (382) | −1.57 (−2.18, −0.95) | 0.69 (0) | 3 (227) | −3.37 (−3.91, −2.83) | 0.50 (0)
No | 5 (1366) | −1.81 (−2.20, 1.41) | 0.79 (0) | 6 (1422) | −2.38 (−2.73, −2.02) | <0.01 (82) | 4 (896) | −2.85 (−3.65, −2.04) | 0.09 (55)
Blinding
Genotypic personnel | 2 (317) | −2.20 (−3.16, −1.25) | 0.61 (0) | 1 (155) | −2.12 (−2.82, −1.41) | NA | 1 (73) | −2.93 (−3.84, −2.02) | NA
No or not reported | 6 (1431) | −2.19 (−2.70, −1.68) | 0.12 (43) | 8 (1649) | −1.81 (−2.40, −1.21) | <0.01 (87) | 6 (1050) | −3.10 (−3.71, −2.50) | 0.08 (49)

CI: confidence interval; d, day; HWE: Hardy-Weinberg equilibrium; N: number of strata in the meta-analysis; PHet: p-value for heterogeneity

* Obayashi and Kimura had 1 and 0 CC homozygotes and therefore are not included in the meta-analyses for the dominant model and for the extreme homozygotes. The African American stratum of Shelleman had 1 TT homozygote and therefore is not included in the meta-analyses for the recessive model and the extreme homozygotes.

#### Key Question #1b Among patients taking warfarin, is there any association between carrying a genotype and biochemical variables, such as therapeutic INR levels?

##### Association between VKORC1 rs9934438 (g.6484C>T) and over anticoagulation

Only one study reported an association between rs9934438 and INR values above 3 or 4 among patients of European and African American descent.61 During the induction phase, the odds for over-anticoagulation (INR >3) were increased among patients of European descent who carry the T allele when compared to CC homozygotes. Statistical analyses were adjusted for dose, having a variant CYP2C9 allele, having a copy of APOE e4, gender, BMI, comedications and other factors. The odds ratio for TT vs. CC was 3.02 (95% CI, 1.20 to 7.57), and that for CT vs. CC was 2.49 (95% CI, 1.46 to 4.25). In adjusted analyses, carriers of at least one copy of the T allele had an OR of 3.10 (95% CI, 1.73, 5.55) for overcoagulation (INR>3). This result was significant in the unadjusted analyses as well. The corresponding adjusted odds ratio for an INR>4 was 11.4 (95% CI, 1.3 to 102.0). This association was not statistically significant in unadjusted analyses. Finally, among patients of African American descent, these associations were not statistically significant.

In any racial subgroup, after dose stabilization, there was no association between over-anticoagulation (defined as either an INR greater than 3 or than 4) and the carriers of rs9934438 polymorphism (P >0.10).

##### Association between VKORC1 rs9934438 (g.6484C>T or c.1173C>T) and time to maintenance dose

Only one study reported an association between rs9934438 and the time to attain dose stability among patients of European and African American descent,61 but there was no association under a dominant genetic model.

##### Effects of environmental factors on the associations

None of the eligible studies reported any interaction between the rs9934438 polymorphism and any environmental factor.

#### Key Question #1a Among patients taking warfarin, is there any association between carrying the genotype and clinical variables, such as the effective dose of warfarin?

##### VKORC1 rs7294 (g.9041G>A or c.3730G>A)

###### Association between VKORC1 rs7294 (g.9041G>A or c.3730G>A) and average warfarin maintenance dose

Eleven studies examined the association between VKORC1 rs7294 (g.9041G>A or c.3730G>A) and mean warfarin maintenance dose for 15 ethnic descent strata (10 European, 4 Asian, and 1 of African American) (Table 2 in Appendix 2). Data for meta-analyses were available in four studies with 498 patients52,58,59,67 (3 European strata and 1 Asian strata). None of the four studies deviated significantly from HWE-predicted proportions (exact P > 0.14 for all four studies). Numerical data were not reported in the remaining seven studies.

Among seven studies that did not provide quantitative data, three reported significant associations between rs7294 and mean warfarin maintenance dose (Figure 2.1). The effects of rs7294 in these three studies were in the same direction as those identified in the meta-analyses.39,51,65 One additional study had no significant association between rs7294 and mean warfarin maintenance dose.56 In the remaining two studies (describing 6 ethnic descent strata), results on this association were not reported.36,63

Overall, in 498 analyzed patients under a dominant genetic model, the mean maintenance dose among carriers of the A allele was higher than it was in GG homozygotes (Figure 2.3, panel A). Under a recessive model, AA homozygotes had a higher average maintenance doses (405 patients) than did those with the AG or GG genotypes (Figure 2.3, panel B). Compared with GG homozygotes, patients with AA genotypes had higher mean maintenance doses (231 analyzed patients) (Figure 2.3, panel C). No statistical heterogeneity was noted across strata in these analyses. As a result of the small number of studies, no subgroup or sensitivity analyses were performed.

###### Association between VKORC1 rs7294 (g.9041G>A or c.3730G>A) and other outcomes

None of the studies evaluated the association between the rs7294 polymorphism and over-anticoagulation outcomes or time to achieve stable maintenance dose, and none evaluated interactions between the polymorphism and environmental factors.

Figure 2.3 Individual and pooled estimates for an association between VKORC1 rs7294 and mean warfarin maintenance dose

A) Dominant model for rs7294 (AG+AA vs. GG), B) Recessive model for rs7294 (AA vs. AG+GG), and c) Extreme homozygotes for rs7294 (AA vs. GG)

X-axis indicates Mean diff: mean difference in the average daily maintenance dose of warfarin (in mg). Kimura had 0 GG homozygotes and therefore is not included in panels B and C.

#### Key Question #1 Among patients taking warfarin, is there any association between carrying the genotype and clinical variables, such as the effective dose of warfarin?

##### VKORC1 rs8050894 (g.6853C>G or c.1542G>C)

###### Association between VKORC1 rs8050894 (g.6853C>G or c.1542G>C) and mean warfarin maintenance dose

The seven studies that examined the association between VKORC1 rs8050894 (g.6853C>G or c.1542G>C) and mean warfarin maintenance dose29,30,39,51,59,63,64 included nine ethnic descent strata (5 European and 4 Asian) (Table 2 in Appendix 2). Data needed for meta-analyses were available from 4 studies29,30,59,64 (1,139 patients; 2 European strata and 2 Asian strata). None of the four studies deviated significantly from the HWE-predicted proportions (exact P > 0.14 for all four studies).

No numerical data were available for meta-analysis, but qualitative data were available for 3 studies.39,51,63 In two of these three studies, significant associations with mean warfarin maintenance dose were reported in the same direction as the meta-analysis (Figure 2.1). 39,51 One study by Tham (3 ethnic descent strata) used haplotype-based analyses and did not mention results specifically on rs8050894.

Overall, under a dominant genetic model, the mean maintenance dose among carriers of the C allele was lower than it was among GG homozygotes (1,014 analyzed patients; (Figure 2.4, panel A). There was no between-study heterogeneity. Assuming a recessive model, CC homozygotes had an average lower maintenance dose than did patients with the CG or GG genotype (1,139 patients; Figure 2.4, panel B). There was little evidence for between-study heterogeneity in this analysis. When compared with GG homozygotes, patients with CC genotypes had an average lower mean maintenance dose (801 patients; Figure 2.4, panel C); again, there was no statistical heterogeneity across studies. Because only 4 studies were quantitatively analyzed, no subgroup or sensitivity analyses were performed.

###### Association between VKORC1 rs8050894 (g.6853C>G or c.1542G>C) and other outcomes

None of the studies evaluated the association between the rs8050894 polymorphism and over-anticoagulation outcomes or time to stable maintenance dose, and none evaluated interactions between the rs8050894 polymorphism and any environmental factors.

### Summary

Carriers of the three common VKORC1 variants T, G, and C alleles were associated with lower average maintenance warfarin doses than were non-carriers. Data were not adequate to address any other key questions.

Figure 2.4 Individual and pooled estimates for an association between VKORC1 rs8050894 and mean warfarin maintenance dose

A) Dominant model for rs8050894 (CG+CC vs. GG), B) Recessive model for rs8050894 (CC vs. CG+GG), and c) extreme homozygotes for rs8050894 (GG vs. CC)

X-axis indicates Mean diff: mean difference in the average daily maintenance dose of warfarin (in mg). Obayashi had 0 GG homozygotes and therefore is not included in panels A and C.

### Discussion

We found no published information on the association of common VKORC1 variants and clinical outcomes. Meta-analyses of the published literature provide substantial information that three common VKORC1 variants [rs9934438 (g.6484C>T or c.1173C>T), rs7294 (g.9041G>A or c.3730G>A), and rs8050894 (g.6853G>C or c.1542G>C)] affect average warfarin maintenance dose. Carriers of the T, G and C alleles, respectively, have, on average, lower maintenance doses than non-carriers. However, the clinical utility of the routine use of VKORC1 genotyping in anticoagulation clinics is uncertain.

Studies included in the meta-analyses were mostly of patients of European descent, and only limited information was available on other ethnic descent groups (e.g., Asians and African American). We did not identify any evidence for differences in genetic effects on warfarin dose across racial subgroups. This is in agreement with large scale empirical explorations of common genetic variations for common diseases: the effects of genetic factors were consistent across populations of different racial descent, although the frequencies of the genetic risk factors in the populations were very different.69

Moreover, the meta-analyses included only studies that reported sufficient numerical data for a quantitative synthesis. Many studies had data on the same associations, but could not be included in the analyses, because they did not report necessary data. However, the direction of genetic effects in the studies not included in the meta-analyses is the same as in the included studies. We performed meta-analyses only for the differences in the maintenance dose across VKORC1 genotypes for 3 SNPs: rs9934438 (g.6484C>T or c.1173C>T), rs7294 (g.9041G>A or c.3730G>A), and rs8050894 (g.6853G>C or c.1542G>C). Two of these SNPs (namely rs9934438 and rs7294) are in strong linkage disequilibrium between them; in addition, the third SNP (rs7294) as well as at least 2 other SNPs (namely rs9923231 [g.3673G>A or c.-1639G>A] and rs2359612 [g.7566T>C or c.2255T>C]) are also in linkage disequilibrium between them and with the first two. This means that the alleles of these SNPs tend to be inherited together. For this reason all analyses across these SNPs are stochastically dependent (correlated).

In the absence of clinical studies that directly compare using vs not using pharmacogenetic testing with respect to patient-relevant clinical outcomes, the role of pharmacogenetic testing in everyday clinical practice remains unclear. (Meta-) analyses of individual patient data are likely needed to analyze and describe possible interactions between genetic factors, and genetic and environmental factors and their exact effects on warfarin maintenance doses. However, ultimately, the value of pharmacogenetic testing is going to be determined by its ability to affect patient relevant clinical outcomes.