# MTHFR gene polymorphism and response to chemotherapy

## Background

The methylenetetrahydrofolate reductase (MTHFR) gene is located on chromosome 1p36. Gene polymorphisms can reduce MTHFR enzyme activity. Two common single nucleotide polymorphisms (SNPs) that affect the activity of the MTHFR enzyme are the C-to-T nucleotide transition at position 677 (dbSNP accession number: rs1801133) (which results in an alanine-to-valine substitution) and the A-to-C nucleotide transversion at position 1298 (dbSNP accession number: rs1801131) (leading to an amino acid exchange from glutamine to alanine).129 Reduced enzyme activity has been reported in 677TT and 1298CC homozygotes, as well as in combined carriers and to a lesser extent, in heterozygous individuals.129–135

The C677T polymorphism is the most frequent MTHFR polymorphism. Homozygotes (677TT) have 30% of the normal MTHFR enzyme activity, whereas heterozygotes (677CT) have 60% of the normal activity.132 The C677T mutation increases the thermolability of MTHFR, which leads to lower levels of 5-methyltetrahydrofolate, an accumulation of 5,10-methylenetetrahydrofolate, and increases in plasma homocysteine levels in individuals with marginal folate status. The resulting changes in cellular composition of one-carbon folate derivatives may also impair remethylation of homocysteine to methionine and lead to DNA hypomethylation.

The MTHFR A1298C gene polymorphism also decreases enzymatic activity, but to a lesser extent than does the MTHFR C677T gene polymorphism. The in vivo functional relevance of the A1298C variant is less well defined. A1298C affects in vitro enzyme function to a lesser degree, and individuals carrying the variant often have normal homocysteine and plasma folate concentrations.132

These MTHFR SNPs often appear in the literature with alternative designations, such as Glu429Ala or E429A for A1298C and Ala222Val or A222V for C677T 129–135.

### MTHFR and chemotherapy

Folate is vital in DNA synthesis, and polymorphisms in the MTHFR gene may affect the response of cancer cells to chemotherapy. Two commonly used chemotherapeutic agents, 5-fluorouracil (5FU) and methotrexate (MTX), competitively interact with folate metabolism. In addition, MTHFR polymorphisms can lead to the accumulation of 5,10-methylenetetrahydrofolate that can affect the chemotherapeutic response of cancer cells.133

Alterations in the intracellular pool of folates caused by MTHFR polymorphisms can increase toxicity in patients receiving antifolate therapy. According to the common toxicity criteria of the National Cancer Institute, five of six patients who experienced grade-4 toxicity in their first cycle of adjuvant chemotherapy with cyclophosphamide, methotrexate and 5-FU for early breast cancer had the variant 677TT MTHFR genotype. In these patients, the antifolate, methotrexate, potentiated 5-FU toxicity as a result of thymidilate synthase inhibition by a covalently bound ternary complex and probably contributed to severe acute toxicity.136–138

We investigated MTHFR gene polymorphisms in patients with solid or hematologic cancers and determined their effect on the response to chemotherapy.

### Data synthesis and analyses of MTHFR gene polymorphism with chemotherapy

For each study, the odds ratio (OR) and corresponding 95% confidence interval (CI) of responders versus non-responders to chemotherapy for the allele of each gene polymorphism were extracted or calculated from each article. Studies for the same type of cancers were combined in meta-analysis.

## Results

Of 136 abstracts screened for eligibility (Appendix 1), 11 studies that investigated the association between any of the MTHFR C677T or MTHFR A1298C gene polymorphisms and response to chemotherapy of the folate metabolic pathway were included (Table 4.1).129–134,136–140

Table 4.1 Characteristics of the 11 Studies Evaluating the Association between the MTHFR Genotype and Response to Chemotherapy

Characteristics | Description: number of studies (references)
Total | 11 studies129–134,136–140
Ethnicity | Caucasians: 8^129,131–134,136,139,140^ Asians: 2^129,137^ Mixed: 1^138^
Countries | North America: 2^131,138^ Europe: 7^129,132–134,136,139,140^ Asia: 2^130,137^
Types of cancers | Upper gastrointestinal cancers: 4^129,133,138,140^ Lower gastrointestinal cancers: 6^131,132,134,136,137,139^ Cervical cancer: 1^130^
Commonly examined polymorphisms | C677T: 10^129–134,136,137,139,140^ A1298C: 4^132,134,136,139^

The studies were published between 2003 and 2006 (Table 4 in Appendix 2). Eleven studies involved the MTHFR C677T gene polymorphism129–134,136,137,139,140 and six involved the MTHFR A1298C polymorphism 130,132,134,136,138,139. The final outcome of chemotherapy was classified as response or no response, using different criteria (e.g., shrinkage of tumor, histological evaluation, recurrence). Studies varied in their definitions of complete response (disappearance of the disease) or partial response (at least 50% reduction in tumor load of the lesions), stable disease (≤25% progression or <50% shrinkage) or cancer progression (size enlargement >25% or appearance of new lesions). The definitions of outcomes for individual studies are shown in Table 4 in Appendix 2.

Overall, the number of responders and nonresponders, respectively, was 561 and 667 for MTHFR C677T and 266 and 254 for MTHFR A1298C. The most common genotypes in both responders and nonresponders were genotypes MTHFR 677 CT and MTHFR 1298 AA, and the most common alleles were C and A, respectively.

### Key Question #1 Among patients undergoing chemotherapy, is there any association between carrying the genotype and complete response, partial response, or stable disease?

#### MTHFR C677T

No study showed significant associations among the alleles (T vs. C), the recessive model (TT vs. TC+CC), and the dominant model (TT+TC vs. CC) (Figures 4.1–4.3).129–134,136,137,139,140

#### Colorectal cancer

Six studies investigated the association between the response to chemotherapy and comparison between alleles (MTHFR 677T vs. C). The studies showed significant heterogeneity (P = 0.05, I^2^ = 54%) among them131,132,134,136,137,139 (Table 4.2). The pooled odds ratio, under a random-effects model, was not significant (OR: 0.97; 95% CI, 0.65 to 1.46). The recessive and dominant models for allele T showed non-significant associations (OR: 1.48; 95% CI, 0.67 to 3.25) and (OR: 0.72; 95% CI, 0.42 to 1.23), respectively.

A subgroup analysis of Caucasians (from five studies)131,132,134,136,139 found no significant association for the allele contrast (OR: 1.05; 95% CI, 0.66 to 1.67). The recessive and dominant models showed similar results. Genotype data were not reported by age group, tumor type, or tumor stage.

The Egger test and the Begg-Mazumdar test for the comparison between alleles (MTHFR 677T vs. C) indicated that there is no differential magnitude of effect in large versus small studies (P = 0.14 and P = 0.17, respectively).

#### Gastric cancer

Two studies in Caucasians129,140 found no significant association between the response to chemotherapy and comparison between alleles (MTHFR 677T vs. C) (OR: 0.78; 95% CI, 0.47 to 1.31). The recessive and dominant models for allele T also produced non-significant associations (OR: 0.61; 95% CI, 0.18 to 2.04) and (OR: 0.77; 95% CI, 0.38 to 1.56), respectively (Table 4.3). No study reported genotype data by age group, tumor type, or tumor stage.

#### Esophageal cancer

Two studies130,135 found no significant association between the response to chemotherapy and the dominant models for allele T (OR:1.09, 95% CI, 0.64 to1.84) (Table 4.4).

#### Cervical cancer

One study130 found no significant associations between response to chemotherapy and MTHFR C677T genotype in cervical cancer.

##### MTHFR A1298C

No study showed a significant association for the allele contrast (C vs. A), the recessive model (CC vs. CA+AA), or the dominant model (CC+CA vs. AA) (Figures 4.4–4.6).

#### Colorectal cancer

Four studies of Caucasians investigated the association between the response to chemotherapy and comparison between alleles (1298C vs. A).132,134,136,139 Heterogeneity among the four studies was significant (P = 0.09, I^2^ = 54%).132,134,136,139 The pooled odds ratio, under a random-effects model, was not significant (OR: 0.94; 95% CI, 0.58 to 1.52). The recessive and dominant models for allele C also produced non-significant associations (OR: 0.95; 95% CI, 0.26 to 3.50) and (OR: 0.94; 95% CI, 0.54 to 1.65), respectively (Table 4.5). Genotype data were not reported by age group, tumor type, or tumor stage.

### Key Question #2 What demographic or clinical variables mediate the association between pharmacogenomic test results and response to chemotherapy?

### Key Question #3 How does the pharmacogenomic test result affect the decision to undergo chemotherapy; that is, how often is therapy changed in response to the test result)?

### Key Question #4 What benefits, harms, or adverse effects are experienced by patients on chemotherapy from treatment received after pharmacogenomic testing?

None of the identified studies investigated demographic or clinical variables that might mediate the association between pharmacogenomic test results and response to chemotherapy (key question 2). In addition, none of the studies investigated whether MTHFR gene testing influenced therapeutic choice (key question 3) or the benefits and harms or adverse effects for patients from their subsequent therapeutic management after gene testing (key question 4).

## Summary

Few studies evaluated the relationship between MTHFR and the response to chemotherapy of folate metabolic pathway. We identified no studies that evaluated key questions 2, 3, or 4.

Table 4.2 Results of the meta-analyses for the association between the MTHFR C677T genotype and the response to chemotherapy in patients with colorectal cancer

Contrast for C677T | Population | No. Studies | Fixed effects OR (95% CI) | Random effects OR (95% Ci) | _I_^2^ (%) | P Q-test
T vs C | All | 6 | 0.92(0.71–1.20) | 0.97 (0.65–1.46) | 54 | 0.05
T vs C | Caucasians | 5 | 0.96 (0.73–1.27) | 1.05 (0.66–1.67) | 60 | 0.04
Recessive model | All | 6 | 1.43 (0.87–2.33) | 1.48 (0.68–3.25) | 50 | 0.07
Recessive model | Caucasians | 5 | 1.56 (0.94–2.61) | 1.75 (0.74–4.13) | 54 | 0.07
Dominant model | All | 6 | 0.68 (0.47–1.00) | 0.72 (0.42–1.23) | 46 | 0.10
Dominant model | Caucasians | 5 | 0.71 (0.48–1.05) | 0.77 (0.41–1.41) | 55 | 0.06

Table 4.3 Results of the meta-analyses for the association between the MTHFR C677T genotype and the response to chemotherapy in patients with gastric cancer

Comparisons for C677T | Population | No. Studies | Fixed-effects OR (95% CI) | Random-effects OR (95% CI) | I^2^ (%) | P Q-test
T vs C | Caucasians | 2 | 0.81 (0.57–1.14) | 0.78 (0.47–1.31) | na | 0.16
Recessive model | Caucasians | 2 | 0.70 (0.37–1.31) | 0.61 (0.18–2.04) | na | 0.20
Dominant model | Caucasians | 2 | 0.78 (0.45–1.35) | 0.77 (0.38–1.56) | na | 0.20

na = non-applicable

Table 4.4 Results of the meta-analyses for the association between the MTHFR C677T genotype and the response to chemotherapy in patients with esophageal cancer

Comparisons for C677T | Population | No. Studies | Fixed-effects OR (95% CI) | Random-effects OR (95% CI) | I^2^ (%) | P Q-test
Dominant model | All | 2 | 0.78 (0.45–1.35) | 1.09 (0.64–1.84) | na | 0.86

na = non-applicable

Table 4.5 Results of the meta-analyses for the association between the MTHFR A1298C genotype and the response to chemotherapy in patients with colorectal cancer

Comparisons for A1298C | Population | No. studies | Fixed-effects OR (95% Ci) | Random-effects OR (95% CI) | I^2^ (%) | P Q test
C vs A | Caucasians | 4 | 0.96 (0.70–1.32) | 0.94 (0.58–1.52) | 54 | 0.09
Recessive model | Caucasians | 4 | 0.89 (0.45–1.78) | 0.95 (0.26–3.50) | 57 | 0.07
Dominant model | Caucasians | 4 | 0.98 (0.65–1.46) | 0.94 (0.54–1.65) | 45 | 0.14

Figure 4.1 Individual odds ratios for the comparison between alleles (MTHFR 677T vs C) and response to chemotherapy, by type of cancer

Figure 4.2 Individual odds ratios for the recessive model of MTHFR 677T and response to chemotherapy, by type of cancer

Figure 4.3 Individual odds ratios for the dominant model of MTHFR 677T and response to chemotherapy, by type of cancer

Figure 4.4 Individual odds ratios for the comparison between alleles (MTHFR 1298C vs. A) and response to chemotherapy, by type of cancer

Figure 4.5 Individual odds ratios for the recessive model of MTHFR 1298C and response to chemotherapy, by type of cancer

Figure 4.6 Individual odds ratios for the dominant model of MTHFR 1298C and response to chemotherapy, by type of cancer

## Discussion

The evidence indicates that MTHFR gene polymorphisms do not predict response to chemotherapy. The results of the present report and meta-analysis were based on a relatively small number of studies and participants and, therefore, should be interpreted cautiously. The relationship between response to chemotherapy and the multiple gene polymorphisms involved in homocysteine-folate metabolism remains unresolved. Ethnicity had no effect on the association between MTHFR gene polymorphisms and response to chemotherapy. We do not know the relationship between effect modifiers such as age and tumor type or stage, and MTHFR gene polymorphisms and the response to chemotherapy because they were not clearly reported in the individual studies. The scarcity of data on MTHFR gene testing and therapeutic choice precluded any inference on this association. Data on the benefits and harms or adverse effects for patients from their subsequent therapeutic management after gene testing are also needed.