# Methods

This evaluation of pharmacogenetic tests for non-cancer and cancer conditions is based on a systematic review of the literature.

## Literature Search Strategy

We conducted a comprehensive search of the peer-reviewed scientific literature to identify relevant studies addressing the key questions. Medline was searched from its inception through September 2007. We used relevant terms for the pharmacogenetic tests and limited the search to studies on humans that were published in English (see Appendix 1 for the complete search strategy). We did not search for unpublished data. Additional searches were conducted through April 2008 of Medline and clinicaltrials.gov to identify published randomized controlled trials, systematic reviews, and ongoing clinical trials of CYP2C9 and VKORC1 for warfarin therapy.

## Study Selection

We assessed titles and abstracts of citations identified from the literature searches using the eligibility criteria listed below. A low threshold was used to retrieve articles. The full text of articles that potentially met the inclusion criteria were retrieved and reviewed for inclusion. References cited in the retrieved studies and selected reviews were examined to identify additional published articles. Duplicate reports or multiple publications of the same article were identified by comparing authors and study recruitment centres. Studies were included only once, except when duplicate reports of the same study provided complementary information. This report addresses four different pharmacogenetic tests. In addition to the general eligibility criteria, each topic also had specific eligibility criteria.

### Population

We included only studies of adult humans who were: taking warfarin and underwent genetic testing for CYP2C9 and VKORC1 SNPs; taking any type of statin and underwent genetic testing for Apo E SNPs; receiving chemotherapy directed to the folate metabolic pathway and underwent genetic testing MTHFR SNPs. When data on racial descent were reported separately, we analyzed the results by racial descent strata.

### Exposure

Relevant tests were those that evaluated specific genetic polymorphisms and that were used in conjunction with specific drug therapy. We included studies that evaluated allelic variants *2 and/or *3 for CYP2C9, various common allelic variants for VKORC1, alleles e2, e3, and e4 for Apo E, and common allelic variants for MTHFR were included (see individual results sections for more details on how the genetic risk factors were selected).

### Comparisons

In each study, we used a dominant genetic model to contrast carriers vs non-carriers of the variant alleles. (In the following sections, we refer to people who do not have the genetic variant of interest as “non-carriers”.) We did not evaluate additive genetic models (i.e., allele-based analyses on an assumption of a constant odds ratio per copy of the variant allele) or other comparisons (e.g., comparison of extreme homozygotes). Details of genetic comparisons are available in individual results sections.

### Outcomes

We included all relevant clinical and laboratory outcomes. The outcomes evaluated are described in detail in each individual results section.

### Design

We accepted studies of any design that recruited at least 10 subjects per group.

## Data Extraction

For each included study, we extracted the following data: year of publication, country, clinical setting, study design, eligibility criteria, patient characteristics, details of the genotyping methodology, therapy used, co-medications, co-morbidities, definitions of outcomes, and baseline and final results for outcomes of interest (Appendix 1 has the data extraction forms). We extracted data for time points as reported in individual studies. All complications (adverse events) were extracted exactly as reported. Data were extracted by single reviewer and verified by a second reviewer. Disagreements were resolved through consensus.

It is difficult to assign a single quality score for pharmacogenetic studies. No established method comprehensively describes all features pertinent to the validity of these studies. In addition, in any study, quality is assessed on information reported in the article and not necessarily on how the study was conducted. Thus, we systematically evaluated individual studies for the following characteristics without assigning a quality score: homogeneity of study groups, whether genotyping personnel was blinded to clinical results, genotyping methodology, replication or verification of genotyping with another protocol, reporting of loss to follow up, clear description of patient recruitment, assessment of deviations of the genotype frequencies from those predicted by the Hardy-Weinberg law (deviations from the Hardy-Weinberg equilibrium [HWE]), assessment of gene-gene interactions, and control for possible clinical (age, sex, severity of disease) and other (smoking, diet) modifiers between genotypes. Details of these items in each study are reported in Appendix 2. In subgroup analyses we examined whether any observed heterogeneity could be explained by these factors.

## Data Synthesis and Analysis

### Meta-Analyses

Generally, when two or more studies made the same comparison, and when the data were sufficient, we performed meta-analyses to identify any association between pharmacogenetic testing results and patient outcomes with therapeutic management. The exception was the analysis of VKORC1 variants and response to warfarin, where meta-analyses were performed when at least 4 studies were available (for practical purposes, since 22 different variants had been studied in the eligible reports).

For the main analyses, we used DerSimonian and Laird’s random-effects model for all syntheses.6 The random-effects model assigns a weight to each study based on both the individual study variance and the estimated between-study heterogeneity. Compared with the fixed-effect model, the random-effects model is more conservative in that it generally results in wider confidence intervals when between-study heterogeneity is present. We tested for heterogeneity using Cochran’s Q and assessed its extent with I^2^. I^2^ expresses the proportion of between-study variability that is attributed to heterogeneity rather than chance.7

### Subgroup, Sensitivity Analyses, and Meta-regression

To address key question 2, we analyzed the data by demographic and disease subgroups. In addition, to exploring potential differences in results across studies and in the presence of significant heterogeneity, further subgroup analyses were conducted based on study-design factors and duration of follow-up. More information is given in the individual result section. Heterogeneity of results across studies was explored by investigating the consistency of estimates between subgroups.

In addition, random effects meta-regression was performed when applicable. Weights were defined as the inverse variance of the odds ratio (OR) incorporating the residual heterogeneity variance. Meta-regression can reveal the effects of particular study characteristics on response to therapy.