# Key Questions Addressed in this Report

The approach, methodology, and criteria for the review were agreed on by consensus of the EPC, CMS, and AHRQ.

## SECTION 1 CYP2C9/VKORC1 - Warfarin

Key Question #1: Among patients taking warfarin, is there any association between genetic variations (SNPs) in CYP2C9 or VKORC1 and:

▪ Clinical variables, such as the effective dose of warfarin?
▪ Biochemical variables, such as therapeutic INR levels?

Key Question #2: Among patients taking warfarin, is there any association between genetic variations (SNPs) in CYP2C9 or VKORC1 and adverse outcomes, such as serious bleeding events or thrombotic events?

Key Question #3: What demographic or clinical variables mediate the association between pharmacogenetic test results and biochemical or clinical outcomes among patients who use warfarin?

Key Question #4: How does the pharmacogenetic test result affect the decision to use warfarin; that is, how often has therapy changed in response to the test result?

Key Question #5: What benefits, harms, or adverse effects are experienced by patients on warfarin from change in treatment received after the pharmacogenetic test results are known?

5a Does pharmacogenetic testing among patients on warfarin and with supratherapeutic INRs result in better maintenance of therapeutic INRs and fewer episodes of serious bleeding?
5b Does pharmacogenetic testing among patients on warfarin and with subtherapeutic INRs result in better maintenance of therapeutic INRs and fewer serious thrombotic events, such as stroke or pulmonary embolus?

## SECTION 2 Apo E – statin therapy

Key Question #1: Among patients taking statin therapy, is there any association between carrying the Apo E genotypes and:

▪ Clinical outcomes, such as cardiovascular events, mortality, or other composite clinical endpoint?
▪ Biochemical variables, such as total, LDL, or HDL cholesterol or triglyceride levels?

Key Question #2: What demographic or clinical variables mediate the association between pharmacogenetic test results and biochemical or clinical outcomes among patients taking statin therapy?

Key Question #3: How does the pharmacogenetic test result affects the decision to use statin therapy; that is, how often is therapy changed in response to the test result?

Key Question #4: What benefits, harms, or adverse effects are experienced by patients on statins from change in treatment received after pharmacogenetic testing?

## SECTION 3 MTHFR-Chemotherapy

Key Question #1: Among patients undergoing chemotherapy, is there any association between genetic variations (SNPs) in MTHFR and complete response, partial response, or stable disease?

Key Question #2: What demographic or clinical variables mediate the association between pharmacogenetic test results and response to chemotherapy?

Key Question #3: How does the pharmacogenetic test result affect the decision to undergo chemotherapy; that is, how often is therapy changed in response to the test result?

Key Question #4: What benefits, harms, or adverse effects are experienced by patients on chemotherapy from change in treatment received after pharmacogenetic testing?