# CYP2C9 Gene Polymorphisms and Response to Warfarin Therapy

## Background

Warfarin is used to manage the risk of arterial and venous thromboembolism.8 As a result of its narrow therapeutic index, managing warfarin therapy is challenging. An insufficient dose will fail to prevent thrombosis, and an excessive dose increases the risk of bleeding complications.9,10

Warfarin anticoagulation is used for very different indications. Typically, when treating patients with warfarin, physicians adjust doses to achieve desirable anticoagulation levels during a treatment induction period. Once the dosing scheme is stabilized patients are kept on a (largely) stable maintenance dose such that their international normalized ratio (INR) is within the desired therapeutic (target) range. Warfarin maintenance doses can vary greatly among patients (ranging from 0.5 mg/day to 60 mg/day).11 For some patients, even seasoned specialists can face difficulties in finding a stable warfarin maintenance dose. Age, body weight, co-medications, comorbid conditions, diet, alcohol consumption, and genetic factors affect patient response to warfarin therapy.

The cytochrome P450 complex is a group of hepatic microsomal enzymes involved in the oxidative metabolism of many drugs. Cytochrome P450, subfamily IIC, polypeptide 9 (CYP2C9), is the principal drug-metabolizing enzyme for warfarin. CYP2C9 inactivates the S-enantiomer of warfarin by hydroxylation. Two variants of CYP2C9 reduce the metabolism of warfarin (CYP2C9*2 (430C>T) and CYP2C9*3 (1075A>C)12 or have been associated with a reduced dose of warfarin13 and an increased risk for bleeding.12,14

Bleeding is a serious complication in patients who are on warfarin. Thromboembolism is also a serious complication among those under-dosed on warfarin therapy. Knowing whether a patient carries the aforementioned gene variants may help identify whether he or she is at an increased risk of bleeding or thromboembolism. At least in theory, warfarin doses could be tailored to take into account each patient’s genetic risk factors. However, it remains unclear whether pharmacogenetic testing has a favorable impact on patient-relevant clinical outcomes.

### Data Synthesis and Analysis for Associations between CYP2C9 Genotypes and Warfarin Therapy

In the following sections, we will be referring to the CYP2C9 alleles CYP2C9 *2 and CYP2C9 *3. CYP2C9 *2 (rs1799853) is also referred to as 430C>T. CYP2C9 *3 (rs1057910) is also referred to as 1075A>C.

We performed meta-analyses of weighted mean differences in the average warfarin maintenance dose and the rate of bleeding complications across genotypes. We contrasted carriers versus non-carriers of the genetic risk factors, essentially assuming a dominant genetic model. More specifically, we contrasted carriers versus non-carries of CYP2C9*2, CYP2C9*3, and either CYP2C9*2 or CYP2C9*3. When studies did not report standard deviations (SD) of the average maintenance dose of warfarin, we imputed means and standard deviations based on medians and ranges.15

Subgroup analyses by ethnic descent (European, Asian) were performed. In sensitivity analyses, we excluded studies in which the genotype proportions deviated significantly from the HWE-predicted proportions and those studies for which we imputed means and standard deviations on the basis of medians and ranges.15

## Results for Section 1: CYP2C9/VKORC1 – Warfarin

The literature search identified 270 citations, from which 63 full-text articles were retrieved. Of these, 29 evaluated CYP2C9 *2 allele and CYP2C9*3 allele and were included in the systematic review,16–44 including three recently published RCTs from the updated literature search.41,43,44 Of 29 studies, 10 recruited patients in the induction phase of warfarin therapy. 21,25,31–33,40–44 Of these 10 studies, three continued follow-up until the maintenance phase. Another 12 of the 27 studies recruited patients in the maintenance phase, when patients were on stable warfarin dosing. The studies were published between 1995 and 2007 (Table 1.1). Appendix 1 presents a flow chart of retrieved and excluded studies, along with the reasons for exclusion.

Table 1.1 Characteristics of 29 studies evaluating associations between the CYP2C9 genotypes and response to warfarin therapy

Characteristics | Description: number of studies (references)
Total | 29 studies16–44
Study design | Prospective cohort: 14^17,18,23,24,26,27,29,30,33–36,39,40^ Retrospective cohort: 8^19–22,25,28,31,32^ Retrospective and Prospective cohort: 2^37,42^ Case-control: 2^16,38^ Randomized controlled trial: 3^41,43,44^
Ethnicity | Caucasians: 12^16,20,25–27,31–34,38,41,42^ Asians: 5^17,29,30,36,39^ Mixed: 6^18,21,24,28,35,43^ Not documented: 6^19,22,23,37,40,44^
Setting | Anticoagulation clinic: 16^16,19–28,34,37–39,42^ Other: 11^17,18,29,30,32,33,35,40,41,43,44^ Not documented: 2^31,36^
Beginning of patient recruitment | Warfarin initiation phase: 10^21,25,31–33,40–44^ Warfarin maintenance phase: 12^16–19,23,24,26,30,34–36,38^ Not documented: 7^20,22,27–29,39,41^
Outcomes assessed | Mean maintenance dose 25^16–40^ Rate of over-coagulation: 6^21,25,32,33,37,40,43,44^ Risk of bleeding: 9^21,25,27,31,33,38,40–44^ Thromboembolism: 2^38,40^

### Key Question #1a Among patients taking warfarin, is there any association between carrying the genotype and the effective dose of warfarin?

Outcomes reported in the studies included warfarin dosage, rate of over-anticoagulation (defined as higher-than-target INR levels as reported in individual studies), rates of bleeding, and rates of thromboembolism or pulmonary embolism.

#### Warfarin dose

Of the 25 studies evaluating warfarin dosing and CYP2C9 genotypes,16–40 five included only Asian populations.17,29,30,36,39 Most (14) studies were prospective cohorts,17,18,23,24,26,27,29,30,33–36,39,40 10 were retrospective cohorts or case control studies,16,19–22,25,28,31,32,38 and one used both research designs.37 Most studies used polymerase chain reaction for genotyping, but only eight replicated or verified their methodology or reported quality controls for genotyping.21,22,28,35,36,38–40 Only two studies reported blinding outcome assessors to genotype.21,27

Twenty of the studies reported that carriers of CYP2C9 *2 allele and CYP2C9*3 allele required significantly lower doses of warfarin than did non-carriers (Table 1.2).16–21,23–25,28–35,37–39 The clinical significance of these differences is unclear.

Table 1.2 Mean differences in maintenance warfarin dose between patients with and without CYP2C9 variant genotypes

Genotype | N studies | N patients | Mean difference in Dose (95% CI), mg/day | Heterogeneity
CYP2C9 *2 allele | 12 | 2530 | −0.8 (−1.05, −0.68) | NS
CYP2C9 *3 allele
Overall | 16 | 3853 | −1.79 (−2.12, −1.45) | <0.05
European descent | 13 | 3367 | −1.79 (−2.17, −1.40) | <0.05
Asian descent | 3 | 486 | −1.76 (−2.34, −1.18) | NS
CYP2C9 *2 or *3 allele
Overall | 18 | 3882 | −1.47 (−1.73, −1.21) | <0.05
European descent | 15 | 3396 | −1.47 (−1.74, −1.20) | <0.05
Asian descent | 3 | 486 | −1.55 (−2.96, −0.40) | <0.05

CI, confidence interval; NS, non significant at the 0.05 level

#### Associations between carriers of CYP2C9 *2 allele and CYP2C9*3 allele and the maintenance dose of warfarin

##### Carriers of CYP2C9*2 allele

Twelve studies (2,530 patients) reported data on the average difference in warfarin maintenance doses between carriers of CYP2C9 *2 allele and all other patients (Figure 1.1).16,19,21,22,25–28,32,34,35,37 Only four of the studies were prospective.26,27,34,35 All 12 studies were conducted in patients predominantly of European or Caucasian descent. Three studies in Asian populations29,30,36 did not identify any carriers of CYP2C9*2 allele among 1,125 patients and are not included in this analyses.

Overall, carrying at least one copy of the CYP2C9*2 allele was associated with a 0.87-mg/day (95% CI: 0.68 to 1.05) lower mean maintenance dose. The clinical significance of these differences is unclear. There was no between-study heterogeneity.

Figure 1.1 Differences in the average daily maintenance dose of warfarin between carriers and non-carriers of the CYP2C9*2 allele

X label axis indicates difference in the mean maintenance dose of warfarin, in mg/day 95%CI, 95% confidence interval; Diff, Difference in the mean maintenance dose of warfarin, in mg, between CYP2C9*2 allele carriers and non-carriers; Eur, Europe; ND, not documented

##### Carriers of CYP2C9*3 allele

Of the 16 studies (3,853 patients) reporting data on the average difference in doses between carriers and non-carriers of CYP2C9 *3 allele,16,21,22,25–32,34–37,39 8 studies were prospective (Figure 1.2).26,27,29,30,34–36,39 The presence of the allele was associated with a 1.79 mg (95% CI 1.45 to 2.12 mg) lower mean maintenance dose, but the between-study heterogeneity was significant. The mean difference in maintenance doses was not significantly different between people of European and Asian descent (1.84 mg vs. 1.55 mg, respectively). There was statistically significant between-study heterogeneity within both racial descent subgroups.

Figure 1.2 Differences in the average daily maintenance dose of warfarin between carriers and non-carriers of the CYP2C9*3 allele

X label axis indicates difference in the mean maintenance dose of warfarin, in mg/day 95%CI: 95% confidence interval; Diff: Difference in the mean maintenance dose of warfarin between *3 allele carriers and non-carriers;

##### Carriers of either CYP2C9*2 or *3 allele

Of 18 studies (3,882 patients) reporting data on the average difference in doses between carriers of either CYP2C9*2 or *3 alleles (Figure 1.3),16,18,21,22,25–30,32,34–40 nine studies were prospective.18,26,27,29,30,34–36,39 Three studies of Asian patients (1,125 patients) found no carriers of CYP2C9*2 alleles.

Overall, carrying at least one variant allele is associated with a 1.47-mg/day (95% CI 1.21 to 1.73 mg) lower mean maintenance dose, with significant between-study heterogeneity. The difference in mean maintenance doses was similar between people of European and Asian descent (1.47 mg vs. 1.55 mg, respectively), and again there was between-study heterogeneity. The results did not change when studies for which we imputed standard deviations were included or excluded from the analyses.

Two studies reported statistically significant odds ratios (OR) for lower warfarin dosing between variant genotype groups. Aithal reported that patients with one or more CYP2C9 variants had a significant six-fold increase in the odds of having a low dose requirement (OR 6.21, 95% CI; 2.48 to 15.6). 16 Taube noted a significant five-fold increase in the odds (OR, 5.42; 95% CI 1.68 to 17.4) of having a lower warfarin mean maintenance dose (1.5 mg or less) in patients with the CYP2C9 *2 allele.37

Two studies reported an association between CYP2C9 *2 or *3 alleles and the time to achieve stable warfarin dosing.21,27 Of these, Higashi reported that the variant genotype group required more time (hazards ratio, 0.65; 95% CI 0.45 to 0.94) to achieve stable dosing.21

No single subgroup explains the observed heterogeneity across study results for CYP2C9 *3 allele and CYP2C9 *2 or *3 allele (Table 1.3). Differences in the average maintenance warfarin dose in all analyses suggested that patients with CYP2C9 *2 alleles consistently had lower maintenance dose requirements. There was no study heterogeneity.

Figure 1.3 Differences in the average daily maintenance dose of warfarin between carriers and non-carriers of either CYP2C9*2 or *3 alleles

X label axis indicates difference in the mean maintenance dose of warfarin, in mg/day; 95%CI: 95% confidence interval; Diff: Difference

Table 1.3 Subgroup and Sensitivity Analyses on the Effects of the CYP2C9 alleles *2 or *3 on Mean Warfarin Maintenance Dose

Subgroup | CYP2C9 *2 carriers vs. non-carriers | | | CYP2C9 *3 carriers vs. non-carriers | | | CYP2C9 *2 or *3 carriers vs. non-carriers
Subgroup
Subgroup | N (patients) | Mean difference, mg/d (95% CI) | P_Het_ (I^2^ [%]) | N (patients) | Mean difference, mg/d (95% CI) | P_Het_ (I^2^ [%]) | N (patients) | Mean difference, mg/d (95% CI) | P_Het_ (I^2^ [%])
All studies | 12 (2530) | −0.87 (−1.06, −0.68) | 0.52 (0) | 16 (3853) | −1.79 (−2.12, −1.45) | <0.01 (74) | 18 (3882) | −1.47 (−1.73, −1.21) | <0.01 (64)
Racial descent
European | 12 (2530) | −0.87 (−1.06, −0.68) | 0.52 (0) | 13 (3367) | −1.84 (−2.21, −1.47) | <0.01 (75) | 15 (2757) | −1.47 (−1.74, −1.20) | <0.01 (63)
Asian | NA | NA | NA | 3 (486) | −1.55 (−2.69, −0.40) | 0.01 (79) | 3 (1125) | −1.55 −2.70, −0.40) | 0.01 (78)
Only patients with stable dose
Yes | 5 (678) | −1.07 (−1.45, −0.70) | 0.51 (0) | 6 (887) | −1.79 (−2.12, −1.45) | 0.15 (39) | 8 (1106) | −1.66 (−2.14, −1.18) | 0.01 (62)
No | 7 (1852) | −0.80 (−1.02, −0.59) | 0.50 (0) | 10 (2966) | −1.62 (−2.06, −1.19) | <0.01 (80) | 10 (2776) | −1.36 (−1.67, −1.05) | <0.01 (67)
Prospective study
Yes | 4 (582) | −1.16 (−1.55, −0.78) | 0.65 (0) | 8 (1760) | −1.84 (−2.40, −1.29) | <0.01 (75) | 10 (1841) | −1.64 (−2.01, −1.27) | 0.02 (56)
No | 8 (1948) | −0.78 (−0.99, −0.56) | 0.59 (0) | 8 (2093) | −1.75 (−2.20, −1.29) | <0.01 (77) | 8 (2041) | −1.31 (−1.65, −0.96) | 0.01 (66)
Deviation from HWE
Yes | NA | NA | NA | 1 (185) | −2.58 (−3.11, −2.06) | NA | 1 (185) | −1.70 (−2.34, −1.03) | NA
No | 12 (2530) | −0.87 (−1.06, −0.68) | 0.52 (0) | 15 (3668) | −1.71 (−2.04, −1.38) | <0.01 (70) | 17 (3697) | −1.46 (−1.74, −1.18) | <0.01 (65)
Blinding
Genotypic personnel | 2 (365) | −0.80 (−1.37, −0.24) | 0.66 (0) | 2 (365) | −2.53 (−2.98, −2.09) | 0.74 (0) | 2 (365) | −1.84 (−2.34, −1.34) | 0.57 (0)
No or not reported | 10 (2165) | −0.88 (−1.10, −0.67) | 0.36 (9) | 14 (3488) | −1.66 (−2.00, −1.33) | <0.01 (70) | 16 (3517) | −1.43 (−1.71, −1.15) | <0.01 (66)

CI: confidence interval; HWE: Hardy-Weinberg equilibrium; N: number; P_Het_: p-value for heterogeneity

### Key Question #1b Among patients taking warfarin, is there any association between carrying the variant genotype and therapeutic INR levels?

#### Rate of Over-Anticoagulation (INRs above Therapeutic Levels)

Six studies (Table 1.4) evaluated the risk for over anticoagulation among carriers of CYP2C9 *2 or *3 allele.21,25,32,33,37,40 Two were prospective,33,40 and four, retrospective.21,25,32,37 With few exceptions, (e.g., patients with prosthetic valves), the targeted therapeutic INR was between 2 and 3 in the majority of patients. However, the threshold INR levels defining over-anticoagulation varied across studies from 3 to more than 8. One study (Taube 2000) that used a threshold INR greater than 8 found no association between carrying the CYP2C9 *2 or *3 alleles and INR above the therapeutic threshold.37 Differences in the definitions of over-anticoagulation and the differences in the time interval over which over anticoagulation events were examined precluded meta-analyses.

A positive association was reported between CYP2C9 *2 and *3 alleles and INRs above 3 during the first 2 weeks of anticoagulation therapy.25 The rate of over-anticoagulation among carriers and non-carriers did not differ during the third week of warfarin dose titration for patients with INRs greater than 3 or 4. The four remaining studies found significant associations between CYP2C9 *2 and *3 alleles in patients starting on warfarin with INRs greater than 3 or 4, with relative effects ranging from 1.4 to 11.1 (reported as either risk ratios, or odds ratios, or hazard ratios) (Table 1.4).

Only one study provided a pharmacogenetic tool to assist titrating the warfarin maintenance dose depending on CYP2C9 genotypes.40 Despite the availability of the tool, among 48 orthopedic patients starting on anticoagulation with INRs greater than 4, the hazard ratio for over-anticoagulation was 4.6, suggesting that over-anticoagulation was more common in patients who carried the genetic variants.

Table 1.4 Characteristics of Six Studies Evaluating the Association between the Carrying the CYP2C9 *2 or *3 alleles and Over-Anticoagulation

Study, year | Analyzed only patients initiating warfarin | Stable dose an inclusion criterion | Target INR | Definition of over anticoagulation, INR | N_All_ | *2 or *3 Carriers | Crude genetic effect size
Study, year | Analyzed only patients initiating warfarin | Stable dose an inclusion criterion | Target INR | Definition of over anticoagulation, INR | N_All_ | *2 or *3 Carriers | Metric | *2 or *3 allele carriers
Taube, 2000^37^ | No | No | 2.5 | >8 (over >2 mo) | 561 | 169 | OR | 1.52 (0.64, 3.58)
Lindh, 2005^25^ | Yes | No | 2–3 | >3 (over 1^st^ wk) | 219 | 84 | RR | 2.15 (1.59, 2.92)
Lindh, 2005^25^ | Yes | No | 2–3 | >3 (over 2^nd^ wk) | 217 | 84 | RR | 2.05 (1.51, 2.79)
Lindh, 2005^25^ | Yes | No | 2–3 | >3 (over 3^rd^ wk) | 210 | 84 | RR | 1.00 (0.68, 1.48)
Lindh, 2005^25^ | Yes | No | 2–3 | >4 (over 1^st^ wk) | 219 | 84 | RR | 1.48 (0.80, 2.72)
Lindh, 2005^25^ | Yes | No | 2–3 | I>4 (over 2^nd^ wk) | 217 | 84 | RR | 2.24 (1.64, 3.07)
Lindh, 2005^25^ | Yes | No | 2–3 | >4 (over 3^rd^ wk) | 210 | 84 | RR | 1.27 (0.70, 2.29)
Peyvandi, 2004^33^ | Yes | No | 2–3 | >3 (between days 4 and 24) | 125 | 50 | RR | 2.01 (1.28, 3.15)^a^
Pchelina, 2004^32^ | Yes | No | 2–3 (2.5–3.5 for some) | >3 or 3.5 as applicable (over 4 wk) | 62 | 16 | OR | 11.1 (2.9, 41.9)^b^
Voora, 2005^40^ | Yes | No | 2.5 | >4 (over 40d) | 48 | 16 | HR | 4.6 (1.4, 14.7)^c^
Higashi, 2002^21^ | Yes | No | 2–3 (2.5–3.5 for some) | >4 or 4.5 (over 2.2 y on average) | 185 | 58 | HR | 1.40 (1.03, 1.90)

N_All_: all analyzed patients

a Assuming that all 4 double heterozygotes were over-anticoagulated. The RR would be 2.53 (95% CI, 1.54 to 4.14) if none of the 4 double heterozygotes were over anticoagulated.

b Odds ration would be 14.7 (95% CI, 3.8 to 57.2) if the single double-heterozygote was not over-anticoagulated

c Based on the maximum P value reported for this hazard ratio (0.01)

Three studies evaluated the time to reach the target INR.21,32,42 Two studies reported no significant differences between the carriers and non-carriers of CYP2C9 *2 or *3 alleles,21,42 while the third reported that the time to reach therapeutic INR for non-carriers was significantly longer than it was for carriers of CYP2C9 *2 or *3 alleles.32

None of the studies reported any statistically significant interactions between patient- or disease-related factors and the genetic variants for time to achieving the therapeutic INR range.

### Key Question #2 Among patients taking warfarin, is there any association between carrying the genotype and adverse outcomes, such as serious bleeding events or thrombotic events?

#### Risk of bleeding complications

Nine studies examined the association between bleeding complications and carriers of CYP2C9 *2, *3.^21,25,27,31,33,38,40–42^ Seven provided quantitative data suitable for meta-analysis.21,25,27,31,33,38,40 The two studies that could not be included in the meta-analyses were an RCT that evaluated pharmacogenetic-based warfarin dosing versus standard approaches41 and a retrospective study on warfarin-receiving patients.42 The RCT by Hillman reported lower bleeding complication rates among 18 patients treated with pharmacogenetic-based dosing than among 20 patients treated with standard dosing (11% versus 25%).41 One retrospective study reported that the risk of serious or life-threatening complications among carriers of CYP2C9 *2, *3 was 2 to 3 times higher than it was among non-carriers (P=0.03).42

#### Meta-analyses on the association between CYP2C9*2 and *3 variants and bleeding events

Bleeding events were defined differently in the seven studies included in the meta-analyses.21,25,27,33,38,40 Two studies were prospective27,33 and five were retrospective.21,25,38,40 Only one study21 used the Fihn criteria45 to define serious and potentially life-threatening bleeding. Major bleeding was defined variously as bleeding warranting intervention or additional testing;27 bleeding resulting in a life-threatening or disabling event, or rehospitalization or death;25,40 macroscopic hematuria and melena38; and clinical symptoms or a drop in hematocrit.33 The severity of bleeding was not defined in one study.31

##### Carriers of the CYP2C9*2 allele

The association between CYP2C9 *2 allele and only major bleeding events was reported in five studies (756 patients) (Figure 1.4). Both studies reporting major bleeding events were retrospective.21,38 The pooled odds ratio for increased bleeding events was 1.81 (95% CI, 0.82 to 3.99) favoring patients who do not carry CYP2C9 *2 allele. The pooled estimate after excluding studies with no major bleeding events in any patients or including all studies in the analyses did not change inferences. There was little statistical evidence for heterogeneity in either analysis.

The association between CYP2C9 *2 allele and bleeding of any severity was not significant (OR, 1.64; 95% CI, 0.85 to 3.18) (Figure 1.5). This analysis excluded the two studies with no bleeding events in any genotypic group. However, including all studies in the analyses resulted in a statistically significant odds ratio for increased bleeding events. There was no statistical heterogeneity in either analysis.

Figure 1.4 Individual and pooled estimates for an association between warfarin treatment and major bleeding events in patients with and without the CYP2C9 *2 allele

X label axis indicates odds ratio (OR) and ratio greater than 1 indicates increased major bleeding events in the carriers of CYP2C9 *2 allele.

Figure 1.5 Individual and pooled estimates for an association between warfarin treatment and bleeding events of any severity in patients with and without the CYP2C9 *2 allele

X label axis indicates odds ratio (OR) and ratio greater than 1 indicates increased bleeding events in the carriers of CYP2C9 *2 allele.

##### Carriers of the CYP2C9*3 allele

The association between carriers of CYP2C9 *3 allele and major bleeding events was assessed in five studies (756 patients; Figure 1.6). Both studies that reported major bleeding events were retrospective.21,38 In three of the five studies, major bleeding rates ranged from 0 percent to 31 percent (8/26) among carriers of CYP2C9 *3 allele and from 0 percent (3 studies) to 16 percent (24/159) among non-carriers. Excluding studies without major bleeding events in any patients, the pooled odds ratio for major bleeding was 4.37 (95% CI 1.02 to 18.8) favoring patients who do not carry CYP2C9 *3 allele. Including all studies in the analyses resulted in a pooled odds ratio of 3.62 (1.65 to 7.94). Heterogeneity was not statistically significant in either analysis. With the exception of Higashi,21 genotype distributions of patients taking warfarin were not statistically different from HWE-predicted proportions. When corrected for deviations from the HWE-predicted proportions, the pooled estimates did not change appreciably.21

The association between carrying CYP2C9 *3 allele and bleeding of any severity was significant (OR 1.90, 95% CI 1.21 to 2.97) in Figure 1.7. Including studies with no events in the analyses did not change the inferences, and there was no significant heterogeneity among studies.

Figure 1.6 Individual and pooled estimates for an association between warfarin treatment and major bleeding events in patients with and without the CYP2C9 *3 allele

X label axis indicates odds ratio (OR) and ratio greater than 1 indicates increased major bleeding events in the carriers of CYP2C9 *3 allele.

Figure 1.7 Individual and pooled estimates for an association between warfarin treatment and bleeding events of any severity in patients with and without the CYP2C9 *3 allele

X label axis indicates odds ratio (OR) and ratio greater than 1 indicates increased bleeding events in the carriers of CYP2C9 *3 allele.

##### Carriers of either CYP2C9*2 or *3 alleles

The association between carrying either CYP2C9*2 or *3 alleles and major bleeding events was evaluated in five studies (756 patients). Two of the studies did not clearly distinguish events of at least “major” severity. In the remaining three studies, major bleeding rates ranged from 0 percent to 28 percent (16/58) among carriers of either alleles. Among people who did not carry CYP2C9*2 or *3 alleles, rates were 0 percent in 4 studies and 13 percent (16/127) in the Higashi study.21 Excluding studies with no major bleeding events in any patients, the pooled odds ratio was non-significant: 3.78 (95% CI 0.89 to 16.02), favoring patients who do not carry CYP2C9*2 or *3 alleles (Figure 1.8). Including all studies in the analyses resulted in a significant pooled odds ratio of 2.92 (95% CI 1.43 to 5.97). Heterogeneity was statistically nonsignificant for both analyses. The association between carrying CYP2C9 allele *2 or *3 and bleeding of any severity compared to non-carrier was significant, with an OR of 1.80 (95% CI 1.12 to 1.90) (Figure 1.9). Including all studies in the analyses did not change the inferences, and there was no statistical heterogeneity.

Figure 1.8 Individual and pooled estimates for an association between warfarin treatment and major bleeding events in patients with either the CYP2C9*2 or *3 allele and patients with neither allele

X label axis indicates odds ratio (OR) and ratio greater than 1 indicates increased major bleeding events in the carriers of CYP2C9 *2 or *3 allele.

Figure 1.9 Individual and pooled estimates for an association between warfarin treatment and bleeding events of any severity in patients with either the CYP2C9 *2 or *3 allele and patients with neither allele

X label axis indicates odds ratio (OR) and ratio greater than 1 indicates increased bleeding events in the carriers of CYP2C9 *2 or *3 allele.

#### Association with the Risk of Thromboembolism

Two studies reported that patients with CYP2C9*2 or *3 alleles had rates of thromboembolism or pulmonary embolism while on warfarin therapy that were similar to those of patients with no variants.38,40 It was not clear whether these two studies actively monitored the occurrence of thromboembolic events, or whether these were passively reported.

### Key Question #3 What demographic or clinical variables mediate the association between pharmacogenetic test results and biochemical or clinical outcomes among patients who use warfarin?

Of 25 studies, 10 assessed genetic effects on the average warfarin maintenance dose and provided additional data on patient- and disease-related factors that may explain the inter-individual variability of warfarin dosing.20–27,35,36 Across all studies, patients’ age at the start of warfarin therapy, along with genotype, significantly influenced the variability in warfarin dosing among patients. Patient age and the allele contributed 20 percent to 33.7 percent of the inter-individual variability.

Two studies examined the association between age and warfarin dose for the carriers and non-carriers of CYP2C9 *2, *3.^24,26^ In a two-way ANOVA test evaluating the combined effect of age and CYP2C9 genotypes, patients 66 years and older at least one copy of CYP2C9 *3 required a lower mean (SD) daily dose than did younger patients with the CYP2C9 *1/*1, (2.2 (1.2) mg versus 7.9 (3.7) mg, respectively; P < 0.001).26 Warfarin dose depends on age, and the relationship between age and dose was different for the carriers and non-carriers of CYP2C9 *2, *3.^24^ In this study, simple linear regression analyses of the carriers and non-carriers of CYP2C9 *2, *3 revealed an inverse relationship between maintenance warfarin dose and advancing age only among carriers of CYP2C9 *2, *3.

Other notable factors that influenced warfarin dosing for the carriers and non-carriers of CYP2C9 *2, *3 included body weight in four studies,20,22,35,36 sex in two studies,22,24 co-medications that are metabolic inducers of warfarin in one study,20 and diabetes in two studies.21,41 All four studies consistently reported that patient’s body weight had a significant linear relationship with warfarin dose in the variant groups. Two studies examined the association of sex and warfarin dosing in the carriers and non-carriers of CYP2C9 *2, *3 reported discordant results on the interaction of sex.22,24 Although Hillman, in a multivariate analysis, concluded that being male accounted for 5 percent of the variability in dosing,22 Linder24 found no statistically significant association between sex and warfarin dosing in the carriers and non-carriers of CYP2C9*2, *3.

One study reported a significant interaction between local bleeding and gene variants.27 In multivariate analyses, in addition to the gene variants, female sex, the source of bleeding, and the duration of bleeding were associated with an increased risk of bleeding.

### Key Question #4 How does the pharmacogenetic test result affect the decision to use warfarin; that is, how often is therapy changed in response to the test result)?

We identified three published RCTs on pharmacogenetic testing of CYP2C9 and warfarin dosing,41,43,44 two of which compared genotype-guided warfarin dosing with standard warfarin dosing beginning from the induction phase.43,44 Hillman reported that the rate of bleeding complications among 18 patients treated with pharmacogenetic-based dosing was lower than among 20 patients treated with standard dosing (11% versus 25%).41

Caraco randomly assigned 191 patients to receive warfarin in the induction phase, either by six different CYP2C9 genotype-adjusted algorithms (study group) or by a validated algorithm that did not include genetic information (control group).44 Patients were followed for 2 years. Investigators were blinded to patient genotype until after the completion of the induction phase, at 8 weeks. The study did not report the accuracy of the CYP2C9 genotype-adjusted algorithms.

Groups were similar at baseline, except that controls were significantly more likely to have a second indication for warfarin (deep venous thrombosis and pulmonary embolism) and to have the clinical characteristics of hyperlipidemia. The proportion of patients with the CYP2C9*1/*1 was higher in the study group than in control group. The primary endpoints of the study were time to restore INR to a therapeutic range of greater than 2 and time to reach stable anticoagulation defined as two consecutive INR values within 1-week were within the therapeutic range, without any intervening dose alteration. The study group reached both a therapeutic INR and stable anticoagulation significantly earlier by 2.7 days and 18.1 days, respectively than the control group. Higher proportions of study group patients were within a therapeutic INR range for longer periods, and study patients experienced fewer minor bleeding events than did controls. This study did not evaluate the influence of VKORC1 in the variability of warfarin maintenance dose. Different follow-up times were reported for each group. The results were evaluated first for day 1–8 for both groups, then for days 9–22 for study group and days 9–40 (approximately) for control group. The interpretation of the percent time in therapeutic range is difficult.

Anderson compared 101 patients treated with pharmacogenetic-guided dosing to 99 patients treated with standard dosing in an RCT.43 Pharmacogenetic-guided dosing was derived from a regression equation based on 3 genetic variants (CYP2C9 *2 and *3, and VKORC1 1173C>T), age, sex, and weight. Patients were followed up for 3 months. At baseline, the study group included more number of older patients and a higher proportion of patients with hypertension, and the control group had a higher proportion of variant genotypes. The primary end point was the per-patient percentage of out-of range INR (<1.8 or >3.2) measurements. The groups did not differ on the primary outcome, but the study group required statistically significantly fewer dosing changes and fewer INR measurements than did the control group. Patients who carried both CYP2C9 and VKORC1 had an increased risk (26 of 57 patients; P=0.01) for an INR of 4 or higher, and the pharmacogenetic dosing group had more adverse events, defined as clinical events plus instances of INRs of 4 or higher, than did the standard dosing group. Finally, individuals with wild type genotype required significantly increased dose of Warfarin compared to the standard model. While that did not result in a significant difference in out of range INRs (primary endpoint), the authors note that both multiple variant allele carriers and wild-type patients experienced a 10% reduction in out of range INRs with pharmacogenetic guidance. Of note, both Caraco and Anderson used different standard loading dose. These trials indicate the need for consensus with regard to the warfarin induction therapy and to develop a prediction model for a loading dose.

### Key Question #5 What benefits, harms, or adverse effects are experienced by patients on warfarin from treatment received after the pharmacogenetic test results are known?

5a. Does pharmacogenetic testing among patients on warfarin and with supratherapeutic INRs result in better maintenance of therapeutic INRs and fewer episodes of serious bleeding?

5b. Does pharmacogenetic testing among patients on warfarin and with subtherapeutic INRs result in better maintenance of therapeutic INRs and fewer serious thrombotic events, such as stroke or pulmonary embolus?

We identified no studies that evaluated key question 5 or its subquestions.

#### Published reviews and ongoing clinical trials

The meta-analysis of 11 studies by Sanderson reported that patients with CYP2C9 *2 or *3 required 1.4 mg/day lower mean maintenance warfarin doses and had twice the risk for bleeding complications than non-carriers. The authors concluded that the clinical utility and cost-effectiveness of genotyping should be assessed before recommending routine testing.12

A rapid ACCE review of CYP2C9 and VKORC1 published in February 2008, which included selected grey literature sources, determined that although the analytic validity was at least 98% for CYP2C9 genotyping, the evidence for analytic validity was weak for both genotypes.46 The review also reported strong evidence for the clinical validity of both genes in predicting stable warfarin dose. However, the evidence was weak for the association between CYP2C9 testing and severe bleeding, and no studies assessed the association between the presence of VKORC1 and severe bleeding. Data documenting the clinical utility of genotyping before warfarin initiation were not yet available at the time of the review.

On the basis of this ACCE review, the American College of Medical Genetics issued a policy statement and guidelines for using pharmacogenetic testing of CYP2C9 and VKORC1 to change therapeutic goals and to reduce adverse events from warfarin therapy.47 The statement concluded that the evidence is not yet sufficient to recommend for or against routine CYP2C9 and VKORC1 testing in warfarin-naïve patients. The statement also identified the need for additional prospective clinical trials to provide direct evidence for the utility of CYP2C9 and VKORC1 pharmacogenetic testing in the setting of initial warfarin dosing. Ongoing clinical trials are summarized in Table 1.5

#### Summary

Several studies have evaluated the use of CYP2C9 gene polymorphisms in guiding warfarin maintenance dosing. Carriers of the variant CYP2C9 genotypes *2 or *3 require lower mean maintenance doses than do non-carriers. Four of six studies found significant associations between INRs greater than 3 or greater than 4 and patients on maintenance warfarin with CYP2C9 genotypes *2 or *3. However, studies found no significant differences between the carriers and non-carriers of CYP2C9 *2, *3 in the time to reach target INR. The rates of major bleeding were higher in the CYP2C9 genotypes *2 or *3 than in the CYP2C9 genotype *1/*1, but the differences were not statistically significant.

No studies evaluated whether pharmacogenetic testing among patients who are on warfarin and who have supratherapeutic INRs will result in better maintenance of therapeutic INR, fewer episodes of serious bleeding, or fewer serious thrombotic events.

Table 1.5 Ongoing Clinical Trials of Warfarin Dosing Based on Pharmacogenetic Testing of CYP2C9 and VKORC1

Official title (Clinical trials.gov identifier) | Study Design | Intervention Comparator | Primary Outcome | Country where Conducted; Current status
Prospective CYP2C9 And VKORC1 Genotyping for Total Hip or Knee Replacement Patients Receiving Warfarin (Coumadin) For Anticoagulation (NCT00634907) | Treatment, Randomized, Open Label, Active Control, Parallel Assignment, Safety/Efficacy Study | Pharmacogenetic-based warfarin dosing Usual care of warfarin dosing | Reduction in the number of adverse events associated with warfarin anticoagulation after total hip and total knee replacement from the time of warfarin initiation to 3 months after completion of warfarin therapy | US Recruiting
Prospective Evaluation Comparing Initiation of Warfarin StrategiEs (PRECISE): Pharmacogenetic-Guided Versus Usual Care (NCT00634907) | Treatment, Randomized, Single Blind, Dose Comparison, Parallel Assignment, Safety/Efficacy Study Phase IV | Pharmacogenetic-based warfarin dosing Usual care of warfarin dosing | Accuracy of the initial versus the stable warfarin dose, measured as mean absolute difference in initial versus stable dose | US Recruiting
A Controlled Clinical Pharmacogenetic Study of a CYP2C9 Plus VKORC1 Polymorphism-Based Individualized Dosing Algorithm for Warfarin to Increase Efficiency of Achieving Therapeutic Dosing (NCT00334464) | Treatment, Randomized, Double-Blind, Active Control, Parallel Assignment, Pharmacokinetics Study | Pharmacogenetic-based warfarin dosing Usual care of warfarin dosing | A comparison of the per-patient percentage of out-of-range INRs (<2, >3) over the observation period of up to 3 months | US Recruiting
Warfarin Induction Regimen Based Upon CYP2C9, VKORC1 Factor VII Genotyping, PMR and INR Monitoring, as Compared to the Conventional Regimen: a Prospective Controlled Study (NCT00162435) | Treatment, Randomized, Single Blind, Active Control, Parallel Assignment, Pharmacokinetics/Dynamics Study | Pharmacogenetic-based warfarin induction Conventional regimen | Warfarin clearance Maintenance dose of warfarin at steady state. Time to reach INR >2, pharmacodynamic steady state. Time spent at therapeutic INR <3 and >2; >3; <2 Incidence of minor and major bleeding episodes. | Israel Recruiting
Study of the Association of Warfarin Dosage and Plasma Enantiomer Concentration With the Gene Polymorphisms of CYP and VKOR (NCT00247702) | Treatment, Randomized, Open Label, Placebo Control, Single Group Assignment | Not documented | Not documented | Taiwan Recruiting
Warfarin Dosing: Pharmacogenetic Algorithm Compared to Pharmacist's Dosing (NCT00511173) | Diagnostic, Randomized, Single-Blind, Active Control, Parallel Assignment, Safety/Efficacy Study | Pharmacogenetic-Algorithm-based dosing Warfarin dosing by pharmacist | Not documented | US Recruiting
Creating an Optimal Warfarin Nomogram (CROWN) Trial (NCT00401414) | Treatment, Non-Randomized, Open Label, Uncontrolled, Single Group Assignment, Safety/Efficacy Study | Genetic testing and nomogram modified warfarin induction and maintenance dosing | Frequency of maintaining the target INR using the Partners nomogram will be compared with a historical control group Extent to which the Partners nomogram misses the target INR | US Recruiting
Modeling Genotype and Other Factors to Enhance the Safety of Coumadin Prescribing (NCT00484640) | Treatment, Randomized, Double-Blind, Active Control, Parallel Assignment, Safety Study | Pharmacogenetic-based warfarin dosing Usual care of warfarin dosing | Weighted time in therapeutic range Absolute deviation from clinically optimal dose | US Not yet open for patient participation
Prospective Study Comparing Between the Commonly-Used and Pharmacogenetically Guided Warfarin Administration Protocols (NCT00654823) | Cohort, Prospective | Novel pharmacogenetic model for predicting warfarin (Coumadin) dose response None | ND | Israel Not yet open for patient participation

#### Discussion

For the majority of the studies evaluating CYP2C9 gene polymorphisms and warfarin therapy, the primary outcome was the effect on the warfarin maintenance dose between carriers and non-carriers of genetic variants. Overall, the evidence supports the conclusion that carriers of the variant alleles *2 or *3 have lower average maintenance requirements than do non-carriers. Most of the data pertain to patients of European descent, although studies of Asian patients show similar genetic effects.

CYP2C9 variants are also associated with increased rates of bleeding complications among patients in induction phase. This association was true for all bleeding complications, irrespective of severity, as well as for major bleeding complications that required assistance or intervention. The studies did not explicitly describe whether the association between genotype and adverse clinical outcomes occurred in patients with normal or supratherapeutic INR ranges. Because of marked differences in the definition of bleeding complications across studies, and the possibility of selective reporting for this outcome, the pooled effect sizes from the corresponding meta-analyses should be interpreted with caution. Additionally majority of the association data were from a variety of observational studies that included cross-sectional, retrospective, and prospective designs. While most of the studies reported associations of warfarin and CYP2C9 with regard to bleeding events and overmedication, studies in general, failed to report the outcome of thrombotic events and under dosing. Thrombotic events could be considered only in prospective studies in which patients with variant genotypes are given a lower dose due to the patient’s genotype.

The clinical utility of genetic testing for CYP2C9 in everyday clinical practice is not straightforward. Currently, physicians use rules of thumb to select a starting dose for warfarin treatment and rely on phenotypic (INR) feedback to titrate maintenance doses. It is unclear whether dose-prediction algorithms using genetic information improve clinical outcomes (fewer bleeding complications and fewer thromboembolic events) over those of standard practice. Only a few clinical trials have addressed this question, essentially three RCTs, each of which has their flaws in the design, inclusion criteria and power to reach statistical conclusions. Additionally, there are new genetic associations that are currently under investigation, such as the relationship between genetic variations in cytochrome 4F2 (CYP4F2) and response to warfarin.48 Evaluating the interactions among CYP2C9, VKORC1, and CYP4F2 variants (i.e., gene-gene interactions) as well as gene-environmental interactions can result in better risk predictive instruments for clinical use.

Although we used a different analytic methodology to evaluate pharmacogenetic testing of CYP2C9 among warfarin-treated patients, our results are consistent with those from the ACCE review and the American College of Medical Genetics guideline on the pharmacogenetic testing of CYP2C9 and VKORC1 in changing therapeutic goals and reducing adverse events related to warfarin therapy. 46,47 Several ongoing trials may provide answers in the near future. Depending on these results, future overall conclusions might greatly change with regard to the clinical utility of the pharmacogenetic tests.