# Conclusion

In this report, we examined a large and varied literature on four pharmacogenetic tests for treatment of three non-cancer conditions and one cancer condition. Our systematic review found that the majority of studies evaluated the associations of pharmacogenetic test results with intermediate, not clinical, outcomes, such as the effectiveness of drug dose, and adverse clinical outcomes, such as bleeding events. Only a few studies evaluated the effects of patient- and disease-related characteristics on the association between test results and intermediate or clinical outcomes. Across all four topics, no studies investigated the influence of gene testing on the impact of therapeutic choices and on the benefits and harms or adverse effects for patients from their subsequent therapeutic management after pharmacogenetic testing.

## Limitations and Future Research Recommendations

Genetic meta-analyses have been criticized for lack of consistency in selecting genotypes.141–143 In practice, it is not easy to define a priori the proper, biologically meaningful genotype comparisons, because the actual inheritance models are unknown.144 Early work in the candidate gene era suggests that associations based on highly selected genotype comparisons are almost 10 times more likely to be refuted than other associations.145

Detailed patient-level analyses of outcomes such as warfarin dosing are needed to derive and validate an algorithm that incorporates genetic information and to define the risk for bleeding complications and thromboembolic events among people who carry genetic variants. As described in several examples in the literature, and encouraged by the Network of Networks initiative,146–148 meta-analysis of individual patient data is a particularly suitable framework for such efforts. A consortium of investigators has already been assembled to derive an optimal dose-prediction algorithm, and further efforts to quantify genetic associations with clinical outcomes should be encouraged.

Another major limitation of our analyses is that we included studies with significant diversity in terms of clinical diagnosis, co-morbidities, polypharmacy, and outcome definitions. Future analyses with more studies of homogeneous groups, with strict inclusion criteria and definitions of phenotypes and responses to therapy, may alter the current findings. Moreover, if researchers can make their data on individual patients readily available, adjusted estimates for the effects of modifiers (such as age or tumor stage) can also be analyzed.