# Background

Genetic tests are frequently used to assess persons at risk for a heritable health condition, to confirm the diagnosis of a condition, and to guide treatment decisions. These tests may provide insights into the individual variability in drug responses. The information from pharmacogenetic testing, when applied in a clinical setting, could potentially identify non-responders and those likely to suffer adverse drug reactions, and thus could prevent the prescription of unsafe or ineffective drugs.

The results of diagnostic tests initiate a cascade of decisions on further testing, prevention, or treatment, which determine the course of illness and the cost of healthcare for patients. In 2005, $56 billion was spent on diagnostic services in the US.1 Although diagnostics account for only 1.6% of total Medicare costs, they influence 60 percent to 70 percent of treatment decisions.2

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ) an assessment of pharmacogenetic tests for patients with non-cancer and cancer conditions relevant to the Medicare population. AHRQ assigned this report to the following Evidence-based Practice Center: the Tufts Medical Center Evidence-based Practice Center (Tufts EPC) (Contract No. 290-02-0022), who had previously produced two “horizon scans” on gene tests currently in clinical use and development. These reports identified 62 gene tests for cancer conditions and several hundred tests for non-cancer conditions. Five or six new gene tests become commercially available each month.

In this report, the Tufts EPC describes its systematic review of pharmacogenetic tests that evaluate cancer and non-cancer conditions common in the Medicare population. Tests that have recently been or are currently being reviewed by other groups at CMS or AHRQ (eg, Her-2/neu testing for solid tumors) were excluded. Also excluded were tests with such a large number of published studies that the literature could not be reviewed within the contracted period. Tests that qualified for a focused evaluation were: 1) testing for selected single nucleotide polymorphisms (SNPs) in the cytochrome P450, subfamily IIC, polypeptide 9 gene (CYP2C9) with respect to responses to warfarin therapy, 2) testing for selected SNPs in the Vitamin K epoxide reductase subunit protein 1 gene (VKORC1) with respect to responses to warfarin therapy, 3) testing for selected SNPs in the apolipoprotein E gene (Apo E) with respect to responses to statin therapy, and 4) testing for a SNP in the methylenetetrahydrofolate reductase gene (MTHFR) for responses to antifolate chemotherapy. Details on the examined SNPs are given in the corresponding sections.

Tufts EPC used the general methodological approach for evaluating gene expression profiling and gene tests: ACCE.3 ACCE takes its name from its four components of evaluation— Analytic validity, Clinical validity, Clinical utility, and associated Ethical, legal, and social implications. The process includes collecting, evaluating, interpreting, and reporting data about DNA (and related) testing for disorders with a genetic component in a format that allows policy makers to have access to up-to-date and reliable information for decision making.

Because the CMS requested reviews on the clinical validity and utility of pharmacogenetic tests, the Tufts EPC also used the 6-level hierarchical model frequently used for evaluating diagnostic technologies as a base for this review.4,5 Diagnostic tests are most commonly evaluated on 6 criteria: a) their technical feasibility and optimization; b) their diagnostic accuracy; c) their diagnostic thinking impact; d) their impact on subsequent therapeutic choices; e) their impact on patient outcomes; and f) their societal impact. Pharmacogenetic tests are considered here as diagnostic and prognostic tests for predicting a patient's response to a specific drug. This report focuses on the association between pharmacogenetic test results and the therapeutic impact and patient outcomes of specific therapies.