# Evidence tables of included studies

Appendix 2 Table 1 Study and population characteristics of studies reporting gene variants and warfarin stable dose among patients

Author, yr | Country Setting | Race | N subjects (N excluded) | Age yr | Male% | Study design | Target INR reported in the study | Stable dose as an inclusion criteria | Genotypes | Genotype methodology | Methodology replicated? Or quality control described? | Blinding | HWE assessed
Obayashi, 2006 45 | Japan, CVD unit | Asian 100% | 125 (0) | 62.5 (SD 13.1) | 51% | P | ND [Mean INR 2.12 ± 0.44] | Yes Fixed warfarin dose for at least 2 mo | CYP2C9 *3 VKORC1 | PCR AvaII and KpnI | ND | ND | No
Mushiroda, 2006 46 | Japan, Hospital | Asian 100% | 790 (38) | 68 (19–92) | 67% | P | ND | ND | CYP2C9*3VKORC1 | PCR | ND | ND | No
Moridani, 2006 47 | Canada and US Anticoagulation clinic | Caucasian 94%; other 6% | 189 (0) | 62–71 | 56% | R | ND | ND | CYP2C9*2, *3 | PCR AvaII and NsiI | Yes | ND | Yes
Veenastra, 2005 48 | Hong Kong – China, Anticoagulation clinic | Asian 100% | 69 (28) | 58 (SD 10) | 46% | P | 1.8–3.2 | ND | CYP2C9*3 | PCR | Yes | ND | ND
Herman, 2005 49 | Slovenia Anticoagulation clinic | Caucasian 100% | 188 (0) | 71.9 (SD 9.0) | 50% | R | ND | ND | CYP2C9*2 or *3 | ND | ND | ND | ND
Tabrizi, 2002 50 | US, Hospital Inpatient and outpatient | Caucasian 78% Afr American 22% | 153 (0) | 58.7 (SEM1.2) | 56% | P | 1.8 – 3.5 | Yes <10% dose fluctuation over 4 wk | CYP2C9*2, *3 | TDI-FP PCR | Yes | ND | ND
Scordo, 2002 51 | Italy, Anticoagulation outpatient | Caucasian 100% | 93 (0) | 68 (SD 11) | 61% | P | 2.0 – 3.0 | Yes ≤15% variation over 3 visits | CYP2C9*2, *3 | PCR AvaII and NsiI | ND | ND | Yes
Loebstein, 2001 52 | Israel, Anticoagulation outpatient | Caucasian, 100% | 174 (0) | 63 (SD 15) | 56% | P | ND | Yes ± 20% INR values for 4 clinic visits | CYP2C9*2, *3 | PCR AvaII, NsiI and KpnI | ND | ND | ND
Freeman, 2000 53 | US Inpatient | Caucasian 81% Afr American 19% | 38 (0) | 55.62 (SD 14.95) | 58% | P | 2.0–3.0 | Yes <10% variation in the last 4 wk | CYP2C9*2 or *3 | PCR AvaII, NsiI and KpnI | ND | ND | Yes
Furuya, 1995 54 | UK Anticoagulation clinic | ND | 100 (6) | ND | ND | R | 2.0–4.0 | Yes Stable over 3 consecutive visits | CYP2C9 *2 | PCR AvaII | ND | ND | ND
Chern, 2006 55 | Taiwan Cardiac surgery clinic | 100% Chinese | 37(202) | 51.6 (SD 11.5) | 54% | P | 2.0–3.0 | Yes Stable over 3 months | CYP2C9 *3 | PCR HpaI | ND | ND | ND
Kamali, 2004 56 | UK Anticoagulation clinic | ND | 121 | 72 (24–90) | 55% | P | 2.0–3.0 | Yes Stable over 3 clinic visits | CYP2C9*3 | PCR AvaII, NsiI and KpnI | ND | ND | ND
Linder, 2002 57 | US Anticoagulation clinic | Caucasian 98% Afr American 2% | 56 | 69(12.5) | 55% | P | 2.0–3.0 | Yes Stable over 3 months | CYP2C9*2, *3 | Same as Aithal | ND | ND | Yes
Takahashi, 2006 58 (only data for Japanese CYP2C9 is included; Caucasian data part of Scorda study) | Japan ND | Asian 100% | 172 | 61 (11) | 59% | P | 1.5–2.5 | Yes Stable over 1 month | CYP2C9*3 | PCR | ND | ND | Yes
Hillman, 2004 59 | US Anticoagulation clinic | ND | 453 (17) | 70.6 | 56.7% | R | ND | ND | CYP2C9*2, *3 430C>T 1075A>C | PCR | Yes | No | Yes
Higashi, 2002 60 | US Anticoagulation clinic | Caucasian 96.2% Other 3.8% | 185 (36) | 59.9 | 63.8% | R | 2.0–3.0 | NA; recruited at induction | CYP2C9 *2, *3 | PCR | Yes | Yes | Yes
Lindh, 2005 61 | Sweden Anticoagulation clinic | Caucasian 100% | 219(3) | 61 | 58% | R | 2.0–3.0 | ND | CYP2C9 *2, *3 430C>T 1075A>C | PCR | No | No | Yes
Margaglione, 2000 62 | Italy Anticoagulation clinic | Caucasian 100% | 199 (19) | 41 (15–84) | 55% | P | NA | ND | CYP2C9 *2 *3 | PCR (blood leukocytes) | ND | Yes | No
Aithal, 1999 63 | UK Anticoagulant clinic | Caucasian 100% | 36 cases | Cases: 73 (55–88) | Cases: 47% | Cc | 2.0–3.0 | Yes for at least 3 consecutive visits | CYP2C9 *2, *3 | PCR AvaII and NsiI | ND | ND | Yes
Aithal, 1999 63 | UK Anticoagulant clinic | Caucasian 100% | 52 controls | Controls: 70.5 (33–94) | Controls: 50%
Peyvandi, 2003 64 | Italy Hospital based | Caucasian 100% | 125 (0) | 50 | 69% | P | 2.–3.0 | NA (initiation phase study) | CYP2C9 *2, *3 | PCR (same as Taube) | ND | ND | ND
Pchelina, 2005 65 | Russia Outpatient and inpatient | Caucasian 100% | 62 (236) | 47.6 | ND | R | 2.5–3.5 | NA (initiation phase study) | CYP2C9 *2, *3 | PCR KpnI, AvaII, Mph 1103 | ND | ND | Yes
Hillman, 2005 66 | US Inpatient and outpatient | Caucasian 100% | 38 (79) | 70.5 (standard dosing) 68.8 (model based dosing) | 44% (standard dosing) 45% (model based dosing) | RCT | ND | NA; initiation phase | CYP2C9 *2, *3 | PCR | ND | ND | ND
Ogg, 1999 67 | UK Part of RCT | Caucasian 100% | 233 (nd) | ND | 100% | R | 1.5 | NA (initiation phase study) | CYP2C9 *3 | ND | ND | ND | ND
Topic, 2004 68 | Croatia Anticoagulant clinic | Caucasian 100% | 181 (nd) | 60 | 44 % | Cc | ND | Yes ( > 1 month) | CYP2C9 *2, *3 | PCR AvaII, NsiI and KpnI | Yes | ND | Yes
Voora, 2005 69 | USA Orthopedic patients | ND | 48 (8) | 61 | 58% | P | 2.5 | NA (initiation phase study) | CYP2C9 *2, *3 | PCR AvaII, and KpnI | Yes | ND | Yes
Veenstra, 2005 70 | US Anticoagulant clinic | Caucasian 100% | 196 (4) | 60 | 63.8% | R; P | 2.0–3.0 | NA (initiation phase study) | CYP2C9 *2, *3 | PCR | Yes | ND | Yes
Taube 2000 71 | UK Anticoagulant clinic | ND | 561 (122) | ND | ND | R; P | <2.5 | ND | CYP2C9 *2, *3 | PCR AvaII, NsiI | ND | ND | Yes
Anderson 2007^98^ | USA ND | Caucasian 95% | 200 (6) | 63 | 50% | RCT | 1.8–3.2 | NA | CYP2C9 *2, *3 VKORC1 | PCR | Yes | ND | ND
Caraco 2008^99^ | Israel ND | ND | 191 (283) | 59 | 49% | RCT | 1.8–3.4 | NA | CYP2C9 *2, *3 | PCR | Yes | Yes | Yes

Table 2 Characteristics of the identified studies on VKORC1 gene variations among patients receiving warfarin

Author, year | Country Setting | Ethnic descent | N enrolled (N analyzed) | Age Mean (SD) or [range] | Male [%] | Study design | Target INR reported in the study | Stable dose as an inclusion criteria | Genotype method | Methodology replicated? Or quality control described? | Blinding | rs7294 | rs8050894 | rs9923231 | rs9934438
D’Andrea, 2005^72^ | Italy, Anticoagulation clinic | European | 203 (147)^1^ | Med 43 [15–84] | 54 | Retrospective | ND | ND | PCR | ND | ND | √ | | | √+
Rieder, 2005^73^ | US, Anticoagulation clinic | European | 1^st^ cohort: 186 (186); Validation: 368 (368) | ND | ND | Retrospective | ND | No | PCR | ND | ND | √- | √- | √- | √-
Sconce, 2005^74^ | UK, anticoagulation clinic | ND | 1^st^ cohort: 297 (297) Validation: 38 (38) | 1^st^ cohort: 68 [26–90] Validation: 72 [39–91] | 54 50 | Prospective | 2–3 | Yes (3 visits, ≥3 mo) | PCR | ND | ND | | | √
Vecsler, 2005^75^ | Israel, Anticoagualtion clinic | European-Jewish | 100 (100) | 62 [18–88] | 52 | Retrospective | ND | Yes (for ≥ 3 mo) | PCR | Yes^2^ | ND | | √
Wadelius, 2005^76^ | Sweden, Anticoagulation clinic | European | 201 (201) | 67 [28–88] | 67 | Retrospective | ND | No | PCR | Yes^3^ | ND | √ | | √ | √-
Aquilante, 2006^77^ | US, Anticoagulation clinic | European (91%) African-American (7%) Other (2%) | 350 (350) | 69 [22–89] | 87 | Retrospective | 2–3 (n=311); 2.5–3.5 (n=35); 3–4 (n=4) | Yes (3 visits) | PCR | No | ND | √- | | √+
Carlquist, 2006^78^ | USA, Anticoagulation clinic | European | 213 (213) | 71 [28–100] | 49 | Prospective | 2–3 | Yes (for ≥ 1 mo) | PCR | ND | ND | | | | √+
Herman, 2006^79^ | Slovenia, Anticoagulation clinic | European | 165 (165) | 72 (9) | 50 | Retrospective | 2–3 (n=162); 2.5–3.5 (n=3) | Yes (2 visits) | PCR | ND | ND | √ | | | √+
Li, 2006^80^ | US, Anticoagulation clinic | European | 93 (93) | 63 [24–90] | 69 | Prospective | 2–3 (n=77); 2.5–3.5 (n=13); 1.5–2 (n=3) | ND | Sequencing and PCR | ND | ND | √ | √ | | √+
Osman, 2006^81^ | Sweden, Anticoagulation clinic | European | 98 (92)^4^ | ND [22–89] | 67 | Retrospective | 2–3 | ND | PCR | ND | ND | √ | | | √-
Takahashi, 2006^58^ | Japan/US, ND | European (43%); Asian (57%)^5^ | 365 (179)^6^ | 61 (11) | 52 | Prospective | 1.5–2.5 (n=64); 2–3 (n=115) | Yes (for ≥ 1 mo) | PCR | ND | ND | √ | | | √+
Schelleman, 2007^82^ | US, Anticoagulation clinic | European (49%); African-american (51%) | 338 (317) | 59 (ND) | 69 | Prospective | 2–3 | No | PCR | ND | Yes (Geno-typing) | | | | √+
Veenstra, 2005^48^ | Hong Kong – China, Anticoagulation clinic | Asian | 69 (41) | 58 (10) | 46 | Prospective | 1.8–3.2 | ND | PCR | Yes | ND | √ | √
Yuan, 2005^83^ | Taiwan-China, Anticoagulation clinic | Asian^7^ | 104 (104) | 58 (15) | 54 | Prospective | 1.4–3 | Yes (for ≥3 wk) | PCR | ND | ND | | | √
Tham, 2006^8,84^ | Singapore, Anticoagulation clinic | European (Indian, 13%); Asian (87%) | 215 (215) | 56 (13) | 56 | Retrospective | 2–3 | Yes (for ≥3 mo) | PCR | ND | ND | √- | √- | √- | √-
Obayashi, 2006^85^ | Japan, CVD unit | Asian | 125 (125) | 63 (13) | 51 | Prospective | ND^9^ | Yes (for ≥2 mo) | PCR | ND | ND | | √ | √ | √+
Mushiroda, 2006^46^ | Japan, Hospital | Asian | 790 (752) | 68 [19–92] | 67 | Prospective | ND | ND | PCR | ND | ND | | √ | √ | √+
Kimura, 2007^86^ | Japan, Cerebrovascular (stroke) patients | Asian | 93 (93) | 68 (11) | 71 | Retrospective | 1.6–2.6 | No | PCR | ND | ND | √ | | √ | √+

1 Because of unavailable samples or other technical reasons.

2 Negative controls

3 Duplicate samples (n=4), excluded SNPs with less than 80% successful calls.

4 180 disease-free Swedish controls (“randomly selected”) were also genotyped.

5 Takahashi also reports genotyping 64 African American participants (they include disease-free people) – however no association with outcomes are reported for these people.

6 Only those with combined VKORC1 and CYP2C9 genotypic information were analyzed.

7 95 disease free Chinese controls and 92 disease-free European controls from the US were also genotyped. This study also included a selected group of 11 Chinese patients with warfarin sensitivity and 5 with warfarin resistance, who are not part of the analyses.

8 Same population as in Lee Clin Pharmacol Ther 2006;79:197–205.

9 Mean INR 2.12 ± 0.44

CVD: Cardiovascular disease; Med: median; mo: month(s); N: number; ND: not described; PCR: polymerase chain reaction; SD: standard deviation; wk: week(s)

Appendix 2. Table 3.1 Study Characteristics

First author: Year: | Country: | Journal | type of study | duration of folow up | Statin Used* | Dosage (mg) | hypolipidaemic diet used | Outcomes assesed#
Tavintharan,2007^1^ | Singapore | Diab Obes Metab | Cohort | 12 weeks | SIMVA – LOVA | SIMVA 10- LOVA 20 | yes | TC,LDL,HDL,TGs
Eiriksdottir,2006^2^ | Iceland | Atherosclerosis | cross-sectional | | Nr | Nr | nr | CRP
Fiegenbaum,2005^3^ | Brazil | Clinica Chimica Acta | Cohort | 6 months | SIMVA | 20 | nr | TC,LDL,HDL,TGs
Pedro-Botet,2001^4^ | USA | Atherosclerosis | cohort-RCT arm | 12 months | ATORVA | 10 | yes | TC,LDL,HDL,TGs
Kajinami,2005^5^ | USA | Atherosclerosis | cohort-RCT arm | 12 months | ATORVA | 10 | yes | TC,LDL,HDL,TGs
Takane,2006^6^ | Japan | J Hum genet | retrospective study | 12 months | PRAVA | 9.4 | Nr | TC,LDL
Pena,2002^7^ | Spain | J Int Med | Cohort | 16 weeks | PRAVA | 20 | yes | TC,LDL,HDL,TGs
Korhonen,2002^8^ | Finland | Eur J Clin Pharmacol | Cohort | | LOVA | 76.8 | yes | TC,LDL,HDL,TGs,ApoA1,CETP
Couture,1998^9^ | Canada | Arterioscler Thromb Vasc Biol | cohort-RCT arm | 6 weeks | SIMVA | 20 | yes | LDL,HDL
Vohl,2002^10^ | Canada | Atherosclerosis | cohort-RCT arm | 6 weeks | SIMVA | 20 | yes | LDL
Gerdes,2000^11^ | Finland, Denmark | Circulation | cohort-RCT arm | 5.4 years | SIMVA | 26.8 | yes | Death, Clinical events
Ballantyne,2000^12^ | USA | JACC | cohort-RCT arm | 12 weeks for lipids / 2.5 years for angiography | FLUVA | 40 | yes | TC,LDL,HDL,TGs, Clinical Events, Angiographical Change of CAD
Sanlehy,1998^13^ | Spain | Metabolism | Cohort | 12 weeks | LOVA | 40 | yes | TC,LDL,HDL, TGs,ApoA1,ApoB,ApoA2
Ordovas,1995^14^ | USA | Atherosclerosis | cohort-RCT arm | 12 months | PRAVA | 40 | yes | TC,LDL,HDL,TGs
Heath,1999^15^ | UK | Atherosclerosis | Retrospective | 12 weeks | SIMVA | 10-20-40 | no | TC,LDL
Garcia-Otin,2002^16^ | Spain | Eur j Clin Invest | cohort-RCT arm | 12 months | ATORVA | 10–20 | yes | TC,LDL,HDL,TGs
Maitland van der Zee,2006^17^ | Netherlands | Acta Cardiol | cohort-RCT arm | 2 years | PRAVA | 40 | Nr | TC,LDL,HDL,TGs, Angiographical Change of CAD
Maitland van der Zee,2002^18^ | Netherlands | Pharmacogenetics | Cohort | 7.2 years/26,244.1 person- years | Statins | Nr | Nr | Mortality, Clinical Events
Marquez-Vidal,2003^19^ | France | Am J Cardiol | Cross-sectional | | Statins | Nr | Nr | TC,LDL,HDL,TGs,ApoA1,ApoB
Maitland van der Zee,2003^20^ | Netherlands | Pharmacogenetics | Cohort | 3 years | statins | Nr | Nr | Discontinuation of Statins
Ojala,1991^21^ | Finland | J Int Med | cohort-RCT arm | 6 and 12 weeks | LOVA | 20–40 | yes | TC,LDL,HDL,TGs
Christidis,2006^22^ | Greece | J Cardiovasc Pharmacol Therap | Cohort | 6 months | ATORVA | 20 | yes | TC,LDL,HDL,TGs, ApoA1,ApoB,ApoE
Drmanac,2001^23^ | USA | J Cardiovasc Pharmacol Therap | Retrospective | nr (at least two observations from baseline for each subject | SIMVA, ATORVA, LOVA, PRAVA | 10-20-40-80 | Nr | LDL,TGs
De Kniff,1990^24^ | Netherlands | Atherosclerosis | Cohort | 12 weeks | SIMVA | 40 | nr | TC,LDL,HDL,TGs
Ye,2003^25^ | China | Chin Med Sci J | Cohort | 12 weeks | SIMVA | 5 | yes | TC, LDL,TGs,ApoB
Watanabe,1993^26^ | Japan | Diab Res Clin Pract | Cohort | 12 weeks | PRAVA | 10 | yes | TC, LDL,HDL, TGs,ApoA1,ApoB,ApoE,ApoCII
Dallinga-Thie,2006^27^ | Netherlands | Diabetes | cohort-RCT arm | 30 weeks | ATORVA | 10,80 | nr | PLTP
Alaupovic,1999^28^ | USA | Atherosclerosis | cohort-RCT arm | 4.3 years | LOVA | 40,80 | yes | TC, LDL, HDL,TGs, ApoA1, ApoB,ApoCII,LP(a),
Carmena,1993^29^ | Canada | Metabolism | Retrospective | 12 weeks | LOVA | 80 | yes | TC, LDL, HDL,TGs
Dergunov,2003^30^ | Russia | Vasc Pharmacol | Cohort | 16 weeks | FLUVA | 40 | yes | TC, LDL, HDL,TGs
Kobayashi,2001^31^ | Japan | J ClinPharmacol | Cohort | 12 weeks | PRAVA | 20 | yes | TC, LDL, HDL,TGs, ApoA1, ApoB,ApoE
O'Malley,1990^32^ | USA | Metabolism | Cohort | 6 weeks | LOVA | 20/40 | yes | LDL, HDL,TGs
Zuccaro,2007^33^ | Italy | Pharmacol Res | Retrospective | nr | Statins | All | nr | TC, LDL, HDL,TGs
Rustemeijer,2001^34^ | Netherlands | Clin Sci | Cohort | 12 weeks | PRAVA | 40 | yes | TGs,Pche
Berglund,1993^35^ | Sweden | J Int Med | Cohort | 12 weeks | PRAVA | 10–20 | nr | TC, LDL, HDL,TGs,ApoE
Chaves,2001^36^ | Spain | J Clin Endoc Metab | Cohort | 6 weeks | SIMVA | 20 | yes | TC, LDL, ApoB
Leitersdorf,1993^37^ | Israel | Circulation | Cohort | 16 weeks | FLUVA | 18.75 | yes | LDL
Nestel,1997^38^ | Australia | Atherosclerosis | cohort, cross-over trial | 12 weeks | SIMVA | 20 | yes | TC, LDL, HDL,TGs
O'Neill,2001^39^ | UK | ATVB | Cohort | 4 weeks | ATORVA | 10 | yes | LDL
Woo,2004^40^ | USA | Stroke | Cross-sectional | - | Statins | Nr | no | ICH
Vega,2004^41^ | USA | Curr Alz Res | Cohort | 6 weeks | Statins | Nr | nr | Non-HDL-C
Leren,1995^42^ | Norway | Eur J Clin Invest | Cohort | 12 weeks | LOVA | 60 | yes | TC, LDL, ApoB
Chasman, 2004^43^ | USA | JAMA | Cohort-RCT arm | 24 weeks | PRAVA | 40 | Yes | TC, LDL, HDL
Thompson,2005^44^ | USA | Pharmacogenomics J | Cohort-RCT arm | 6 weeks | ATORVA (1483 patients) –[FLUVA, LOVA, PRAVA, SIMVA] (1252 patients) | ATORVA 10, FLUVA 20, LOVA 20, PRAVA 20, SIMVA 10 | nr | TC, LDL, HDL,TGs

Abbreviations: nr: non-reported, RCT: Randomized Controlled Trial, ICH: Intracerbral Hemorrhage, CAD: Coronary Artery Disease.

Appendix 2 Table 3.2 Patient inclusion and exclusion criteria for each study

First author: Year: | Inclusion criteria | Criteria of Diagnosis: | Type of Disease: | exclusion criteria
Tavintharan,2007 | DM2 requiring LLT | Nr | Hyperlipidemia-DM2 | poor glycemic control (HbA1c >10.0%), unstable medical conditions that might interfere with the evaluation, impaired renal or thyroid function, TGs>4.5 mmol/L, recent MI
Eiriksdottir,2006 | Random selection - statin treatment | Nr | Unspecified hyperlipidemia | Nr
Fiegenbaum,2005 | hypercholesterolemia requiring LLT | Nr | Hypercholesterolemia | TGs>4.5 mmol/l, DM, unstable medical conditions that might interfere with the evaluation, impaired hepatic, renal or thyroid function.
Pedro-Botet,2001 | primary hypercholesterolemia, >18 years, BMI<32 kg/m^2^, LDL>4.14 mmol/l at week-4 and >3.75 mmol/l at week-2,TGs<4.52 mmol/l. | Nr | Primary hypercholesterolemia, | DM1 or uncontrolled DM2, impaired hepatic or renal function, unstable medical conditions that might interfere with the evaluation, <80% compliance with study medication during the placebo baseline phase, or concurrent participation in another clinical trial. Patients with elevated SGOT,SGPT,CPK, taking any immunosuppressive agent: medications affecting lipid metabolism, possibly interact with study medications, or possibly affect clinical laboratory parameters; and drugs known to be associated with rhabdomyolysis or other lipid-regulating drugs. Patients with other LLT could be screened after a 4-week washout period, except for probucol, which required at least 6 months for washout. DM1 or uncontrolled DM2, impaired hepatic or renal function, unstable medical conditions that might interfere with the evaluation, <80% compliance with study medication during the placebo baseline phase, or concurrent participation in another clinical trial. Patients with elevated SGOT,SGPT,CPK, taking any immunosuppressive agent: medications affecting lipid metabolism, possibly interact with study medications, or possibly affect clinical laboratory parameters; and drugs known to be associated with rhabdomyolysis or other lipid-regulating drugs. Patients with other LLT could be screened after a 4-week washout period, except for probucol, which required at least 6 months for washout uncontrolled DM, impaired hepatic or renal function, no drug compliance, other LLT
Kajinami,2005 | primary hypercholesterolemia, >18 years, BMI<32 kg/m^2^, LDL>4.14 mmol/l at week-4 and >3.75 mmol/l at week-2,TGs<4.52 mmol/l. | Nr | Primary hypercholesterolemia,
Takane,2006 | hypercholesterolemia requiring LLT | Nr | Hypercholesterolemia
Pena,2002 | hypercholesterolemia requiring LLT despite diet | NCEP-ATPIII guidelines | Hypercholesterolemia | | TGs>4.5 mmol/L, DM, other LLT, unstable medical conditions that might interfere with the evaluation, impaired hepatic, renal or thyroid function., secondary hypercholesterolemias, hypersensitivy to statins.
Korhonen,2002 | TC>5 mmol/l during adequate diet and colestipol treatment. FH patients with LDL> 95th percentile for age and sex despite diet FH patients with LDL> 95th percentile for age and sex despite diet MI or angina, TC:5.5–8 mmol/l, TGs<2.5mmo/l, after diet Males and postmenopausal females with recent coronary angiography documenting CAD, and LDL: 2.97–4.91 mmol/l after diet primary lipid disorders (isolated hypercholesterolemia or combined hyperlipidemia) and known apoE after diet Males and postmenopausal females with recent coronary angiography documenting CAD, and LDL>130and< 190, TGs < 350 mg/dl. | FH:TC>8mmol/l with tendon xanthomata or a family history of severe hypercholesterolaemia premature CAD | Primary hyperlipidemia (type IIa, IIb) | DM, impaired hepatic function, symptomatic gallstones, unstable angina, MI or CABG within the previous 2 months, TGs>3 mmol/l,, premenopausal women, secondary hypercholesterolaemia (due to hypothyroidism or nephrotic syndrome) concomitant use of barbiturates, anticonvulsants, anticoagulants, theophylline, quinidine, corticosteroids, cimetidine or regularly used antacids)
Couture, 1998 | | presence of three mutations Δ>15 kb, C646Y, W66G | FH | DM, anorexia nervosa, impaired hepatic, renal or thyroid function, constitutional or pathologically delayed puberty
Vohl,2002 | | presence of three mutations Δ>15 kb, C646Y, W66G | FH | DM, anorexia nervosa, impaired hepatic, renal or thyroid function, constitutional or pathologically delayed puberty
Gerdes,2000 | | Nr | CAD-hyperlipidemia | Nr
Ballantyne,2000 | | quantitative coronary angiography | CAD-hyperlipidemia | MI within six months, TGs>3.39 mmol/L, DM, uncontrolled hypertension, previous CABG or PTCA
Sanlehy,1998 | | FH: severe hypercholesterolemia, tendon xanthomas and/or a family history / isolated hypercholesterolemia-combined hyperlipidemia: WHO criteria | Primary hyperlipidemia | alcoholism, DM, impaired hepatic, renal or thyroid function
Ordovas,1995 | | quantitative coronary angiography | CAD-moderate hypercholesterolemia | uncontrolled hypertension, impaired hepatic, renal or thyroid function, type III hyperlipoproteinemia, congestive heart failure, chronic pancreatitis, dysproteinemia, porphyria, lupus erythematosus, poorly controlled or insulin-dependent DM, likelihood of CABG or PTCA to the qualifying coronary artery within 6 months, cerebrovascular disease, significant gastrointestinal disease, alcoholism, hypersensitivity to statins, other LLT
Heath, 1999 | FH combined hyperlipidemia: baseline TGs < 500 and > 200 mg/dl, LDL<250and>190, 180, 160 or 135 mg dL according to CAD risk | 'definite' FH:LDL>4.9mmol/l and tendon xanthoma (TX) | FH | Nr
Garcia-Otin,2002 | FH combined hyperlipidemia: baseline TGs < 500 and > 200 mg/dl, LDL<250and>190, 180, 160 or 135 mg dL according to CAD risk | combined hyperlipidemia: baseline TGs < 500 and > 200 mg/dl LDL< 250 and > 190, 180, 160 or 135 mg dL according to CAD risk | Combined hyperlipidemia | Nr
Maitland van der Zee,2006 | Males and postmenopausal females with recent coronary angiography documenting CAD, and TC:4–8mmol/l, TG<4mmol/l statin treatment in a large populatio-based cohort study case-control subjects treated with statins in a genetic association study for MI initiation of statin use in a large population-based cohort study | at least one coronary artery with a stenosis of>50% | CAD-normal to moderate hypercholesterolemia | Nr
Maitland van der Zee,2002 | | pharmacy records for statin use | Clinical event (MI, stroke, death) | No
Marquez-Vidal,2003 | | previous MI before 6 months or healthy middle-aged men | MI or healthy men | Nr
Maitland van der Zee,2003 | | pharmacy records for statin use | Discontinuation of statin therapy | initiation of statin therapy during the first 6 months after the start of the study
Ojala,1991 | TC>6.2mmol/l, TGs<4.0mmol/l despite diet | FH: severe hypercholesterolemia, tendon xanthomas and/or a family history / the rest classified as non-familial | Hypercholesterolemia | Nr
Christidis,2006 | Heterozygous FH retrospective analysis of patients treated with statins for hyperlipidemia | Nr | heterozygous FH | DM, impaired hepatic, renal or thyroid function, cardiovascular disease with medications affecting lipid metabolism, TG>4.52mmol/L
Drmanac,2001 | Heterozygous FH retrospective analysis of patients treated with statins for hyperlipidemia | Nr | Unspecified hyperlipidemia | DM, impaired renal or thyroid function, medications affecting lipid metabolism
DeKniff,1990 | Heterozygous FH | FH: severe hypercholesterolemia, tendon xanthomas and/or a family history | heterozygous FH | medications affecting lipid metabolism
Ye,2003 | TC>5.7mmol/L, TGs>2.23mmol/L | Nr TC>5.7mm/l for hypercholesterolemia, Nr for DM | hyperlipidemia | impaired hepatic or renal function, pancreatitis
Watanabe,1993 | TC>5.7mmo/l men and women, aged 45–75 years with duration of DM> 1 year, HbA1c<10%, | | Hypercholesterolemia-DM2 | impaired hepatic, renal or thyroid function, alcoholism
Dallinga-Thie,2006 | TC:4–8mmol/L, TGs:1.5–6mmol/L subjects who had saphenous vein coronary bypass graft surgery 1–11 years prior to study entry retrospective analysis of FH patients having been treated with 80 mgLOVAfor12 weeks | TC:4–8mmol/L, TGs:1.5-–mmol/L | hyperlipidemia-DM2 | nr (I have to look in the DALI study)
Alaupovic,1999 | | LDL:130–175mg/dl, TG<300mg/dl | CAD-CABG-hyperlipidemia | Nr
Carmena,1993 | | FH: severe hypercholesterolemia, tendon xanthomas and/or a family history | heterozygous FH | nr
Dergunov,2003 | controlled HT patientsneeding LLT patients with type II hyperlipidemia requiring LLT | nr | hyperlipidemia-HT | Nr
Kobayashi,2001 | controlled HT patientsneeding LLT patients with type II hyperlipidemia requiring LLT | LDL>150, TG<400mg/dl | type II hyperlipidemia | Fh, TG>400
O'Malley,1990 | FH patients having been treated with LOVA in the previous 6 years patients treated with statins: 50 had clinical symptoms of muscle pain and 50 patients without any significant subjective or objective disturbances total cholesterol >5.0mmol/lbut<8.0 mmol}l;TG>1.8 mmol/l but <5.0mmol/l) with Type II diabetes | FH: persistent primary TC>260,g/dl, pripary hypercholesterolemia in other family members, absence of multiple phenotypes in these family members, tendon xanthomas Muscle pain during statin treatment: pain at the upper girth after limited effort; pain to the lower limbs after minimal effort, e.g. uphill or protracted walking or running; diffuse muscle pain | heterozygous FH | use of probucol in the past 6 months
Zuccaro,2007 | | | hyperlipidemia-statin treatment with and without AE | chronic liver disease, alcoholism, renal disease, serious atherosclerotic disease limiting patient motility, malignant disease at any stage, insulin dependent DM as well as multiple associations with drugs and CYP3 A4 inhibitors (azole antifungals, grapefruit juice, dihydropyridine calcium antagonists, others)
Rustemeijer,2001 | | WHO for DMII | hyperlipidemia-DM2 | oral hypoglycemic agents, primary hyperlipidaemia, secondary hyperlipidaemia due to hypothyroidism or nephrotic syndrome, alcohol or drug use infuencing carbohydrate and lipid metabolism, the use of immunosuppressive drugs, hepatobiliary or endocrine diseases, pancreatitis, porphyria and malignancy
Berglund,1993 | FH patients heterozygous FH with detected mutation on the LDLR gene, age 18 65 yr, and male or female (postmenopausal or adequate anticonceptive method and a negative pregnancy test | nr | heterozygous FH | Nr
Chaves,2001 | FH patients heterozygous FH with detected mutation on the LDLR gene, age 18 65 yr, and male or female (postmenopausal or adequate anticonceptive method and a negative pregnancy test | FH: genetic diagnosis | heterozygous FH | homozygous FH; presence of metabolic, hepatic, renal, or endocrine disease; acute coronary events in the preceding 3 months; treatment with drugs that could affect lipid metabolism (corticosteroids, E, androgens, theophyline, coumarin derivates, barbiturates, antiacids, fish oil preparations, thiazides, or blockers), and ethanol consumption more than 30 g/d. other forms of genetic hyperlipidemia, obese patients, pregnant or lactating women, evidence of any mental, medical, or surgical condition that might influence evaluation of the efficacy, safety, or tolerability of the compound, including surgical impairment of the gastrointestinal tract, liver, or kidneys, or any condition compromising the function of these systems and thereby possibly altering the absorption, distribution, or accumulation or causing impairment of the metabolism or excretion of either fluvastatin or its metabolites. history of MI, angioplasty, or major surgery during the 6 months preceding the study,congestive heart failure, severe or unstable angina pectoris, poorly controlled HT, history of drug abuse or alcohol consumption of more than 50 mL/week, Patients who were taking other investigational drugs, lipid-lowering medications, anticoagulants, hormones , antacids, insulin or oral hypoglycemic agents, erythromycin, ketoconazole, or cyclosporin A
Leitersdorf,1993 | heterozygous FH with detected mutation on the LDLR gene, age 18 patients with combined hyperlipidemia | FH: genetic diagnosis, LDL>190mg/dl, TGs<300, tendon xanthomas, CAD | heterozygous FH
Nestel,1997 | heterozygous FH with detected mutation on the LDLR gene, age 18 patients with combined hyperlipidemia | nr | combined hyperlipidemia | Nr
O'Neill,2001 | patients with refractory heterozygous FH cases with statin treatment in a case-control study for ICH | Hyperlipidemia refractory to treatment was defined as having an LDL-C level of >5 mmol/L despite taking SIMVA (40 mg/d) plus at least 1 other drug, ie, cholestyramine, bezafibrate, or nicotinic acid | heterozygous FH | Nr
Woo,2004 | patients with refractory heterozygous FH cases with statin treatment in a case-control study for ICH | nr | ICH | Nr
Vega,2004 | AD patients starting statin treatment | NINCDS/ADRDA criteria for probable AD | probable AD | TC<160mg/dl
Leren,1995 | FH patients Participants in the PRINCE trial who completed the full protocol and provided informed consent for genomic analysis | Goldstein&Brown criteria | heterozygous FH | Nr
Chasman, 2004 | FH patients Participants in the PRINCE trial who completed the full protocol and provided informed consent for genomic analysis | Nr | Hyperlipidemia | Nr
Thompson,2005 | Hypercholesterolemic Patients | nr | Hypercholesterolemia | Nr

Abbreviations: DM: Diabetes Mellitus, FH: Familial Hyperlipidemia, LLT: Lipid Lowering Therapy, AD: Alzheimer's Disease, MI: Myocardial Infarction, HT: Hypertension, LDLR: LDL-receptor, AE:Adverse Events, CABG: Coronary Artery By-pass Grafting, PTCA: Percutaneous Transluminal Coronary Angioplasty.

Appendix 2. Table 3.4 Cohort characteristics

First author: Year: | Number of patients (M/F) | Racial descent: | Age: | Age at onset: | Hyperli pidemic populati on | Severity of hyperilipi demia | Primary hyperlipid emia included only | % of FH cases | Concomitant conditions | concomitant therapy
Tavintharan,2007 | 96 (nr) | East Asians (chinese) | nr | nr | Yes | Nr | Yes | Nr | 100% DM, 81.3% HT, 21% CAD | 7.3% insulin
Eiriksdottir,2006 | 449 (189/260) | Caucasians | 76±6 | nr | ± | Nr | Nr | Nr | Nr | nr
Fiegenbaum,2005 | 99 (25/74) | Caucasians | 59.2 (10.7) | nr | Yes | Nr | Yes | Nr | 11.1% DM, 61.6 %HT, 17.2 % SM | 23% HRT
Pedro-Botet,2001 | 328 (195/133) | Caucasians (Am whites 96%) | 57.8 (11.3) | >18 | Yes | moderate | Yes | Nr | Nr | No medications affecting lipid metabolism
Kajinami,2005 | 328 (195/133) | Caucasians (Am whites 96%) | 57.8 (11.3) | >18 | Yes | moderate | Yes | Nr | Nr | No medications affecting lipid metabolism
Takane,2006 | 33 (14/19) | East Asians (japanese) | 62.3 (34–83) | >34 | Yes | nr | Nr | Nr | Nr | nr
Pena,2002 | 398 (174/124) | Caucasians | 57.3 (11.6) | Nr | Yes | moderate | Yes | | No DM | nr
Korhonen,2002 | 133 (67/66) | Caucasians | 45.5 (18–63) | >18 | Yes | severe | Yes | yes (39%) | No DM | previous therapy with colestipol for 4 weeks, no other medications affecting lipid metabolism
Couture,1998 | 47 (28/19) | Caucasians (Am whites) | 12.6 (2.3) | >8 | Yes | severe | Yes | 100% | No DM, no HT | nr
Vohl,2002 | 47 (28/19) | Caucasians (Am whites) | 12.6 (2.3) | >8 | Yes | severe | Yes | 100% | No DM, no HT | nr
Gerdes,2000 | 488 (401/87) | Caucasians | 35–70 | >35 | Yes | nr | Nr | Nr | 5% DM, 22% HT, 100% CAD, 31% SM | Nr
Ballantyne,2000 | 324 (269/55) | mixed (mainly whites) | 58.8 (7.9) | >35 | Yes | moderate | Nr | Nr | O% DM, 100% CAD, 20%SM | Nr
Sanlehy,1998 | 106 (68/38) | Caucasians | 54 (12) | nr | Yes | severe | Yes | 15% | 37.7% CAD | 25.4% B-blockers, 13.2% diuretics
Ordovas,1995 | 97 (87/10) | Caucasians (Am whites) | 56.8 | <75 | Yes | moderate | Yes | 0% | 100% CAD | No medications affecting lipid metabolism
Heath,1999 | 76 (31/45) | Caucasians | 48.5 (1.72) | nr | Yes | severe | Yes | 100% | 15% HT, 36% CAD, 11% SM | Nr
Garcia-Otin,2002 | 56 (45/11) | Caucasians | 52 (11) | nr | Yes | severe | Yes | | 2.7% CAD | Nr
Maitland van der Zee,2006 | 307 (307/00) | Caucasians | <75 years | <75 | ± | normal to moderate | Nr | Nr | 100% CAD | Nr
Maitland van der Zee,2002 | 1394 person-years (494/900 person years) | Caucasians | nr | >55 | ± | nr | Nr | nr | 11.4% DM, 47.6% HT, 47.7% CAD, 20.4% SM | Nr
Marquez-Vidal,2003 | 154 (154/00) | Caucasians | 55 (35–64) | >35 | ± | nr | Nr | nr | 87.5% CAD | Nr
Maitland van der Zee,2003 | 798 (334/464) | Caucasians | nr | nr | ± | nr | Nr | nr | Nr | Nr
Ojala,1991 | 212 (89/123) | Caucasians | 55.2 (9.3) | nr | Yes | severe | Yes | 36.8% | Nr | 39.1% BBs, 18.4% diuretics, 5.1% HRT
Christidis,2006 | 134 (68/66) | Caucasians | 52.5 (13.8) | nr | Yes | severe | Yes | 100% | No DM, 22.4% SM | No medications affecting lipid metabolism
Drmanac,2001 | 142 (69/73) | nr | 58.5 | nr | Yes | nr | Nr | nr | No DM | No medications affecting lipid metabolism
De Kniff,1990 | 120 (75/45) | Caucasians | 45.4 | >18 | Yes | severe | Yes | 100% | Nr | No medications affecting lipid metabolism
Ye,2003 | 88 (56/32) | East Asians (Chinese) | 62.3 (3.9) | nr | Yes | severe | nr | 0% | | Nr
Watanabe,1993 | 42 (18/24) | East Asians (japanese) | 51.2 (41–70) | >41 | Yes | severe | nr | Nr | 100%DM | 28% oral hypoglymecis agents, 14% insulin, no drugs affecting lipid metabolism
Dallinga-Thie,2006 | 72 (nr) | Caucasians | 60 (8) | >45 | Yes | Moderate to severe | nr | Nr | 100%DM | Nr
Alaupovic,1999 | 489 (449/40) | Nr | 61.5 | nr | Yes | Moderate | Nr | Nr | 100%CAD | warfarin and placebo
Carmena,1993 | 94 (54/40) | Caucasians (Am Whites) | 46.9 (10.5) | >18 | Yes | severe | Yes | 100% | | Nr
Dergunov,2003 | 67 (67/00) | Caucasians | nr | nr | Yes | moderate | Yes | Nr | 100%HT 9.3%DM, 42.7%HT, 10.7%CAD,1 | BBs, CCB
Kobayashi,2001 | 123 (40/83) | East Asians (japanese) | 59,7 (11.9) | nr | Yes | Nr | nr | 0% | 6.7%SM | Nr
O'Malley,1990 | 134 (59/75) | Caucasians (Am Whites) | 42 (12.6) | >18 | Yes | severe | Yes | 100% | | Nr
Zuccaro,2007 | 100 (55/45) | Caucasians | 61.2 (9.0) | nr | Yes | Nr | Nr | Nr | 6%DM,35% HT, | BBs (24%), CCB (1%), APLT (42%), diuretics (14%), ACEi (20%), HRT (4%)
Rustemeijer,2001 | 45 (nr) | Caucasians | nr | nr | Yes | moderate | No | 0% | 100%DM, | 100% on insulin
Berglund,1993 | 120 (nr) | Caucasians | nr | >18 | Yes | severe | Yes | 100% | | Nr
Chaves,2001 | 42 (18/24) | Caucasians | 44.5 (16.0) | >18 | Yes | severe | Yes | 100% | 0%DM, 21%CAD | Nr
Leitersdorf,1993 | 64 (38/26) | Jewish | 43.0 (12.1) | >18 | Yes | severe | Yes | 100% | | Nr
Nestel,1997 | 66 (44/22) | Caucasians (Australians) | 54 (10) | nr | Yes | severe | Nr | Nr | 27%HT, 36%CAD | Nr
O'Neill,2001 | 21 (15/6) | Caucasians | 51.4 (9.4) | >18 | Yes | severe | Yes | 100% | 61.9%CAD | Nr
Woo,2004 | 78 (39/9) | mixed | 65 | nr | Yes | nr | Nr | Nr | | Nr
Vega,2004 | 39 (nr) | mixed | 73 (1.5) | nr | ± | moderate | nr | no | 0%CAD | Nr
Leren,1995 | 58 (45/13) | Caucasians | 48.3 | >18 | Yes | severe | Yes | 100% | | Nr
Chasman, 2004 | 1536 (1002/534) | Mixed (88.7% Caucasians) | 60.2 (12.5) | nr | Yes | nr | nr | nr | 19.6% DM 62% SM | 15.5% HRT
Thompson,2005 | 1483 (901/582) | Mixed (88% Caucasians) | nr | nr | Yes | severe | nr | nr | nr | Nr

Abbreviations: CAD: Coronary Artery Disease, HT: Hypertension. DM: Diabetes Mellitus, SM: Smoking, HRT: Hormone Replacement Therapy, BB: Beta-Blockers, CCB: Calcium Channel Blockers, ACEi: Angiotensin Converting Enzyme Inhibitors, APLTs: Antiplatelet agents,

Appendix 2. Table 3.5 Results reported from each study

First author: Year: | gender interaction assesed? | gene-gene interactions assesed? | baseline differences in lipid profile phenotypes | genetic contrasts used | Description of major results
Tavintharan,2007 | Yes | no | yes (TC, LDL) | e2 carriers vs e3e3 vs e4 carriers | Baseline TC and LDL levels differed significantly amongst genotypes (adjusted p-values: p=0.017 and p=0.029, respectively). E4 carriers had the highest levels of TC and LDL. E4 carriers had greater percent reduction in TC and LDL compared with e2 carriers(adjusted p values: p=0.038 and p=0.04, respectively)
Eiriksdottir,2006 | no | no | Yes | e2e2+e2e3+e3e3 vs e3e4 vs e4e4 | Carriers of one or two ε4 alleles have significantly lower CRP levels than non-carriers and this effect was observed in a dose-dependent manner. Carriers of one or two ε4 alleles had higher TC and lower TGs levels
Fiegenbaum,2005 | no | no | Nr | e2 carriers vs e3e3 vs e4 carriers | No significant association between ApoE genotype and response to treatment was observed
Pedro-Botet,2001 | yes | no | yes (TC, TGs) | e2 carriers vs e3e3 vs e4 carriers | E2 carriers had higher baseline TC levels and e3e3 subjects had lower TGs levels. In men, e2 carriers had greater percent reduction in TC and LDL while e4 carriers had greater reduction in TG levels, compared with e3e3 subjects. In women, no significant effect was observed
Kajinami,2005 | yes | yes | yes (TC, TGs) | e2 carriers vs e3e3 vs e4 carriers | In male wild type allele homozygotes of the CYP7A1 A–204C polymorphism, e2 and e4 carriers showed larger and smaller reductions in LDL, as compared to e3e3 homozygotes. In addition, in CYP7A1 mutant allele homozygotes, subjects with E4 showed the smallest reduction.
Takane,2006 | No | yes | Nr | NA^*^ | heterozygotes for both CYP7A1 −204C and e4 alleles showed significantly poorer LDL reduction
Pena,2002 | Yes | no | yes (TGs) | e2 carriers vs e3e3 vs e4 carriers | E2 carriers had higher TGs baseline levels. No significant association between ApoE genotype and response to treatment was observed
Korhonen,1999 | No | no | No | e2e3 vs e3e3 vs e3e4 vs e4e4 | No significant association between ApoE genotype and response to treatment was observed
Couture,1998 | No | yes | nr | e2e3 vs e3e3+e3e4 | E2 carriers had greater mean LDL response in FH heterozygotes for a LDL receptor-negative mutation, e2 carriers had greater mean LDL response
Vohl,2002 | No | yes | nr | e2e3 vs e3e3+e3e4 | E2 carriers had greater mean LDL response in FH heterozygotes for a LDL receptor-negative mutation, e2 carriers had greater mean LDL response
Gerdes,2000 | No | no | no | e4 carriers vs non carriers | Simvastatin treatment reduced the mortality risk to 0.33 (0.16–0.69) in e4 carriers and to 0.66 (0.35–1.24) in other patients
Ballantyne,2000 | No | no | no | e2 carriers vs e3e3 vs e4 carriers | e3 homozygites had greater reductions in TC and LDL than e4 carriers. E2 carriers had a greater increase in HDL than the other groups. CAD progression or clinical events did not differ significantly among genotypes.
Sanlehy,1998 | Yes | no | no | e2 carriers vs e3e3 vs e4 carriers | No significant association between ApoE genotype and response to treatment was observed
Ordovas,1995 | Yes | no | yes (LDL) | e2 carriers vs e3e3 vs e4 carriers | e2 carriers had greater percent reduction in LDL
Heath,1999 | No | no | no | e4 carriers vs e3e3 | No significant association between ApoE genotype, gender and response to treatment was observed
Garcia-Otin,2002 | No | no | no | e4 carriers vs non carriers | No significant association between ApoE genotype and response to treatment was observed
Maitland van der Zee,2006 | No | no | yes (LDL,HDL,TC,TGs) | e2 carriers vs e3e3 vs e4 carriers | E2 carriers exhibited the largest improvement in TC, HDL and LDL levels. No significant association between ApoE genotype and “Angiographical Change of CAD” was observed
Maitland van der Zee,2002 | No | no | nr | e4 carriers vs non carriers | The protective effect of statins on “clinical events” was independent of ApoE genotype
Marquez-Vidal,2003 | No | no | Nr | e2 carriers vs e3e3 vs e4 carriers | Statin-treated e4 carriers had increased LDL and ApoB levels in a cross-sectional observation and a lower frequency of adequately controlled subjects in this group
Maitland van der Zee,2003 | Yes | No | yes (HDL) | (e2e4 or e3e3 or e3e4 or e4e4) vs e2e3 | Subjects with e2e2 and e4e4 genotypes showed a trend (though not stastistically significant) towards higher dosages of statin therapy. Relative to subjects with the e2e3 genotype, those with the e4e4 genotype had a risk of 2.28 (95%CI, 1.02–5.12) to discontinue statins within 3 years. In women the relative risk not significant versus 3.18 (05% CI, 1.01–10.03) in men
Ojala,1991 | No | No | yes (HDL) | | E4 carriers had higher HDL baseline levels. No significant association between ApoE genotype and response to treatment was observed
Christidis,2006 | Yes | No | yes (TGs, ApoE) | e2 carriers vs e3e3 vs e4 carriers | E2 carriers had higher TGs and ApoE baseline levels. No significant association between ApoE genotype and response to treatment was observed
Drmanac,2001 | Yes | No | nr | e4 carriers vs non carriers | E4 carriers had a trend toward greater reduction in TGs levels and lower reduction in LDL levels
De Kniff,1990 | Yes | No | no | e2 carriers vs e3e3 vs e4 carriers | Overall, no significant association between ApoE genotype and response to treatment was observed. Female patients with e3e3 genotype responded better in LDL reduction.
Ye,2003 | No | No | yes (TG, ApoB) | e2 carriers vs e3e3 vs e4 carriers | E2 carriers had significantly higher baseline levels of ApoB andTGs. E2 carriers showed significantly greater ApoB reduction
Watanabe,1993 | No | No | yes (TGs) | e2 carriers vs e3e3 vs e4 carriers | E2 carriers had significantly higher baseline levels of TGs. E2 carriers showed significantly lower ApoB reduction
Dallinga-Thie,2006 | No | No | nr | e3e3 vs others | no significant association between ApoE genotype and response to treatment was observed
Alaupovic,1999 | No | No | nr | nr | no significant association between ApoE genotype and response to treatment was observed
Carmena,1993 | Yes | Yes | no | e2 carriers vs e3e3 vs e4 carriers | Male e4 carriers respond less efficiently with respect to TC and LDL levels than e3e3 or e2 carriers or women of any ApoE genotype. However, they respond more efficiently with respect to increasing HDL levels. These effects were idependent of the nature of the LDL receptor defect
Dergunov,2003 | No | No | yes (HDL) | e2 carriers vs e3e3 vs e4 carriers | E2 carriers had higher baseline HDL levels. No significant association between ApoE genotype and response to treatment was observed
Kobayashi,2001 | No | No | yes (ApoE) | e2 carriers vs e3e3 vs e4 carriers | E2 carriers had higher baseline ApoE levels. E2 carriers had significantly greater reductions in TC, LDL and ApoB levels.
O'Malley,1990 | Yes | No | yes (TG) | e2 carriers vs e3e3 vs e4 carriers | E2 carriers had higher baseline TGs levels. No significant association between ApoE genotype, gender and response to treatment was observed
Zuccaro,2007 | No | No | yes (TG) | e2 carriers vs e3e3 vs e4 carriers | E2 carriers had higher baseline TGs levels. E2 carriers had significantly greater reductions in TGs lavels and significantly greater increase in HDL.
Rustemeijer,2001 | No | No | no | e2 carriers vs e3e3 vs e4 carriers | No significant association between ApoE genotype and response to treatment was observed
Berglund,1993 | No | No | yes (ApoE) | e2e3 vse2e4 vs e3e3 vs e3e4 vs e4e4 | E2 carriers had higher baseline ApoE levels. No significant association between ApoE genotype and response to treatment was observed
Chaves,2001 | Yes | Yes | no | e4 carriers vs e3e3 | No significant association between ApoE genotype, gender or LDLR mutation and response to treatment was observed
Leitersdorf,1993 | No | Yes | nr | e4 carriers vs e3e3 | E4 carriers had significantly greater reduction in LDL, irrespective of the LDLR mutation.
Nestel,1997 | No | No | nr | e2 carriers vs e3e3 vs e4 carriers | E2 carriers responded better in TC and TGs lowering
O'Neill,2001 | No | No | nr | e2 carriers vs e3e3 vs e4 carriers | E3e3 homozygotes showed a significantly greater reduction in LDL. Possession of an e4 allele was significantly more frequent among poor responders (6 of 8) than among good responders (3 of 11, P<0.05).
Woo,2004 | No | No | no | e2carriers+e4carrie rs vs e3e3 | E3e3 homozygotes had a reduced risk for ICH e4carrie
Vega,2004 | No | No | nr | e4e4 vs e3e4 vs e3e3 | No significant association between ApoE genotype and response to treatment was observed
Leren,1995 | No | No | no | e4 carriers vs non- carriers | E4 carriers had a significantly lower reduction in TC.
Chasman, 2004 | Yes | Yes | Yes (LDL) | Nr | SNP 17 in the Apo E gene was associated with a greater reduction in LDL cholesterol among individuals heterozygous or homozygous for the minor allele (corrected P=.047). Its effect was attenuated and no longer fully significant in the analysis limited to Caucasians (corrected P=0.22)
Thompson,2005 | no | no | nr | E2 carriers vs e3e3 vs e4 carriers | E2 Caucasians carriers have a 39.9% lowering of LDL following treatment with ATORVA, compared to 36.4% lowering among caucasiand wth e3e3 genotype (p=0.0015). The results for Caucasians treated with the other statins did not show any significant association with ApoE genotype.

Non-Applicable*: The APOE genotypes were presented in combination with CYP7A1 gene polymorphisms

Table 4 Characteristics of eligible studies considered in the report

Author | Year | Country | Ethnicity | No | Median age (range) yrs | Male/ Female | Gene polymo- rphism | Type of cancer | Type of malig- nancy | Clinical outcomes investigated | Responders defined | Non- responders defined | Type of chemotherapy | Tumor stage (Tumor size, lympoma Nodes, Metastasis)
Terrazzino87 | 2006 | Italy | Caucasian | 125 | 60 (31–79) | 80/45 | C677T and A1298C | primary adenocarcin oma of the oma of the rectum (Rectal) | solid | Tumor Regression Grade (TRG) | TRG(1–2) | TRG(3–5) | 5-FU and external beam radiotherapy (median dose 48.4 Gy) | I, II, III, IV (T2-T4, N0-N1, M0-M1)
Suh88 | 2006 | Korea | Asian | 54 | 58 | 30/24 | C677T | metastatic colorectal cancer | solid | CR, PR, SD and DP | CR+PR+SD | DP | FOLFOX chemotherapy (folinic acid, 5-FU and oxaliplatin) | II, III, IV
Ott89 | 2006 | Germany | Caucasian | 135 | 56 (23–70) | 97/38 | C677T | advanced gastric cancer | solid | Histopatholo gical Response Evaluation^*^ | <10% residual tumor cells | all that is not responders | cisplatin and 5-FU | II, III (cT3–4, any N, cM0)
Chung90 | 2006 | South Korea | Asian | 36 | 51 | nr | C677T and A1298C | bulky cervical cancer | solid | Tumor Shrinkage (CR, PR, SD and DP) | CR+PR | SD+DP | 5-FU/platinum agent with or without ADRIA and ETP | Ib2, IIa, IIb
Wu91 | 2006 | USA | Mixed (90% whites) | 210 | 61 (32–79) | 182/28 | C677T and A1298C | esophageal cancer | solid | Recurrence | No Recurrence | Recurrence | FU | IIa-IVb
Ruzzo92 | 2006 | Japan | Caucasian | 175 | 61 (38–79) | 99/76 | C677T | Advanced gastric cancer | solid | CR, PR, SD and DP | CR+PR | SD+DP | FU/cisplatin
Sarbia93 | 2006 | Germany | Caucasian | 68 | 57 (37–70) | 60/8 | C677T | Advanced esophageal squamous cell cancer | solid | CR, PR, SD and DP | CR+PR | SD+DP | FLEP (folinic acid, ETP, 5-FU, cisplatin) | (cT3–4, cN0–1, cM0)
Jakobsen94 | 2005 | Denmark | Caucasian | 139 | 63 | 50/38 | C677T and A1298C | Metastatic colorectal cancer | solid | | | | FU
Etienne95 | 2004 | France | Caucasian | 98 | 64 (40–82) | 57/41 | C677T and A1298C | advanced colorectal cancer | solid | CR, PR, SD and DP | CR+PR | SD+DP | 5-FU and folinic acid | IV (Tx, Nx, M1)
Cohen96 | 2003 | Canada | Caucasian | 43 | 59 (43–70) | 27/16 | C677T | advanced colorectal cancer | solid | CR, PR, SD and DP | CR+PR | DP | 5-FU
Marcuello97 | 2006 | Spain | Caucasian | 94 | 68 (43–83) | 68/26 | C677T and A1298C | colorectal cancer | solid | CR, PR, SD and DP | CR+PR | SD+DP | 5-FU

* The macroscopically identifiable tumor bed of the resected tumors was completely examined histologically.

TRG-1=absence of viable cancer cells in the resected specimen;

TRG-2=presence of residual cancer cells;

TRG-3=fibrosis outgrowing residual cancer cells;

TRG-4=residual cancer cells outgrowing fibrosis;

TRG-5=absence of response.

CR=Complete Response (disappearance of the disease)

PR= Partial Response (at least 50% reduction in tumor load of the lesions)

SD= Stable Disease (≤25% progression or <50% shrinkage)

DP=Disease Progression (size enlargement >25% or appearance of new lesions)

FU=fluorouracil

ADRIA=Adriamycin

ETP=Etoposide

T=Tumor size

N=Node involvement

M=metastasis

Tx=any T

Nx=any N

## Reference List

1 Tavintharan S, Lim SC, Chan YH, Sum CF. Apolipoprotein E genotype affects the response to lipid-lowering therapy in Chinese patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2007;9:81-86. UI: [underlined: 17199722]. [pmid: 17199722].
2 Eiriksdottir G, Aspelund T, Bjarnadottir K, et al. Apolipoprotein E genotype and statins affect CRP levels through independent and different mechanisms: AGES-Reykjavik Study. Atherosclerosis. 2006;186:222-224. UI: [underlined: 16445917]. [pmid: 16445917].
3 Fiegenbaum M, da Silveira FR, Van der Sand CR, et al. Pharmacogenetic study of apolipoprotein E, cholesteryl ester transfer protein and hepatic lipase genes and simvastatin therapy in Brazilian subjects. Clin Chim Acta. 2005;362:182-188. UI: [underlined: 16038892]. [pmid: 16038892].
4 Pedro-Botet J, Schaefer EJ, Bakker-Arkema RG, et al. Apolipoprotein E genotype affects plasma lipid response to atorvastatin in a gender specific manner. Atherosclerosis. 2001;158:183-193. UI: [underlined: 11500190]. [pmid: 11500190].
5 Kajinami K, Brousseau ME, Ordovas JM, Schaefer EJ. A promoter polymorphism in cholesterol 7alpha-hydroxylase interacts with apolipoprotein E genotype in the LDL-lowering response to atorvastatin. Atherosclerosis. 2005;180:407-415. UI: [underlined: 15910869]. [pmid: 15910869].
6 Takane H, Miyata M, Burioka N, et al. Pharmacogenetic determinants of variability in lipid-lowering response to pravastatin therapy. J Hum Genet. 2006;51:822-826. UI: [underlined: 16917677]. [pmid: 16917677].
7 Pena R, Lahoz C, Mostaza JM, et al. Effect of apoE genotype on the hypolipidaemic response to pravastatin in an outpatient setting. J Intern Med. 2002;251:518-525. UI: [underlined: 12028507]. [pmid: 12028507].
8 Korhonen T, Hannuksela ML, Seppanen S, Kervinen K, Kesaniemi YA, Savolainen MJ. The effect of the apolipoprotein E phenotype on cholesteryl ester transfer protein activity, plasma lipids and apolipoprotein A I levels in hypercholesterolaemic patients on colestipol and lovastatin treatment. Eur J Clin Pharmacol. 1999;54:903-910. UI: [underlined: 10192749]. [pmid: 10192749].
9 Couture P, Brun LD, Szots F, et al. Association of specific LDL receptor gene mutations with differential plasma lipoprotein response to simvastatin in young French Canadians with heterozygous familial hypercholesterolemia. Arterioscler Thromb Vasc Biol. 1998;18:1007-1012. UI: [underlined: 9633944]. [pmid: 9633944].
10 Vohl MC, Szots F, Lelievre M, et al. Influence of LDL receptor gene mutation and apo E polymorphism on lipoprotein response to simvastatin treatment among adolescents with heterozygous familial hypercholesterolemia. Atherosclerosis. 2002;160:361-368. UI: [underlined: 11849659]. [pmid: 11849659].
11 Gerdes LU, Gerdes C, Kervinen K, et al. The apolipoprotein epsilon4 allele determines prognosis and the effect on prognosis of simvastatin in survivors of myocardial infarction : a substudy of the Scandinavian simvastatin survival study. Circulation. 2000;101:1366-1371. UI: [underlined: 10736278]. [pmid: 10736278].
12 Ballantyne CM, Herd JA, Stein EA, et al. Apolipoprotein E genotypes and response of plasma lipids and progression-regression of coronary atherosclerosis to lipid-lowering drug therapy. J Am Coll Cardiol. 2000;36:1572-1578. UI: [underlined: 11079660]. [pmid: 11079660].
13 Sanllehy C, Casals E, Rodriguez-Villar C, et al. Lack of interaction of apolipoprotein E phenotype with the lipoprotein response to lovastatin or gemfibrozil in patients with primary hypercholesterolemia. Metabolism. 1998;47:560-565. UI: [underlined: 9591747]. [pmid: 9591747].
14 Ordovas JM, Lopez-Miranda J, Perez-Jimenez F, et al. Effect of apolipoprotein E and A-IV phenotypes on the low density lipoprotein response to HMG CoA reductase inhibitor therapy. Atherosclerosis. 1995;113:157-166. UI: [underlined: 7605354]. [pmid: 7605354].
15 Heath KE, Gudnason V, Humphries SE, Seed M. The type of mutation in the low density lipoprotein receptor gene influences the cholesterol-lowering response of the HMG-CoA reductase inhibitor simvastatin in patients with heterozygous familial hypercholesterolaemia. Atherosclerosis. 1999;143:41-54. UI: [underlined: 10208479]. [pmid: 10208479].
16 Garcia-Otin AL, Civeira F, Aristegui R, et al. Allelic polymorphism-491A/T in apo E gene modulates the lipid-lowering response in combined hyperlipidemia treatment. Eur J Clin Invest. 2002;32:421-428. UI [underlined: 12059987]. [pmid: 12059987].
17 Maitland-van der Zee AH, Jukema JW, Zwinderman AH, et al. Apolipoprotein-E polymorphism and response to pravastatin in men with coronary artery disease (REGRESS). Acta Cardiol. 2006;61:327-331. UI: [underlined: 16869455]. [pmid: 16869455].
18 Maitland-van der Zee AH, Stricker BH, Klungel OH, et al. The effectiveness of hydroxy-methylglutaryl coenzyme A reductase inhibitors (statins) in the elderly is not influenced by apolipoprotein E genotype. Pharmacogenetics. 2002;12:647-653. UI: [underlined: 12439225]. [pmid: 12439225].
19 Marques-Vidal P, Bongard V, Ruidavets JB, Fauvel J, Perret B, Ferrieres J. Effect of apolipoprotein E alleles and angiotensin-converting enzyme insertion/deletion polymorphisms on lipid and lipoprotein markers in middle-aged men and in patients with stable angina pectoris or healed myocardial infarction. Am J Cardiol. 2003;92:1102-1105. UI: [underlined: 14583365]. [pmid: 14583365].
20 Maitland-van der Zee AH, Stricker BH, Klungel OH, et al. Adherence to and dosing of beta-hydroxy-beta-methylglutaryl coenzyme A reductase inhibitors in the general population differs according to apolipoprotein E-genotypes. Pharmacogenetics. 2003;13:219-223. UI: [underlined: 12668918]. [pmid: 12668918].
21 Ojala JP, Helve E, Ehnholm C, alto-Setala K, Kontula KK, Tikkanen MJ. Effect of apolipoprotein E polymorphism and XbaI polymorphism of apolipoprotein B on response to lovastatin treatment in familial and non-familial hypercholesterolaemia. J Intern Med. 1991;230:397-405. UI: [underlined: 1940775]. [pmid: 1940775].
22 Christidis DS, Liberopoulos EN, Kakafika AI, et al. The effect of apolipoprotein E polymorphism on the response to lipid-lowering treatment with atorvastatin or fenofibrate. J Cardiovasc Pharmacol Ther. 2006;11:211-221. UI: [underlined: 17056835]. [pmid: 17056835].
23 Drmanac S, Heilbron DC, Pullinger CR, et al. Elevated baseline triglyceride levels modulate effects of HMGCoA reductase inhibitors on plasma lipoproteins. J Cardiovasc Pharmacol Ther. 2001;6:47-56. UI: [underlined: 11452336]. [pmid: 11452336].
24 De KP, Stalenhoef AF, Mol MJ, et al. Influence of apo E polymorphism on the response to simvastatin treatment in patients with heterozygous familial hypercholesterolemia. Atherosclerosis. 1990;83:89-97. UI: [underlined: 2390138]. [pmid: 2390138].
25 Ye P, Shang Y, Ding X. The influence of apolipoprotein B and E gene polymorphisms on the response to simvastatin therapy in patients with hyperlipidemia. Chin Med Sci J. 2003;18:9-13. UI: [underlined: 12901521]. [pmid: 12901521].
26 Watanabe J, Kobayashi K, Umeda F, et al. Apolipoprotein E polymorphism affects the response to pravastatin on plasma apolipoproteins in diabetic patients. Diabetes Res Clin Pract. 1993;20:21-27. UI: [underlined: 8344125]. [pmid: 8344125].
27 Dallinga-Thie GM, van TA, Hattori H, Rensen PC, Sijbrands EJ. Plasma phospholipid transfer protein activity is decreased in type 2 diabetes during treatment with atorvastatin: a role for apolipoprotein E?. Diabetes. 2006;55:1491-1496. [pmid: 16644710].
28 Alaupovic P, Fesmire JD, Hunnighake D, et al. The effect of aggressive and moderate lowering of LDL-cholesterol and low dose anticoagulation on plasma lipids, apolipoproteins and lipoprotein families in post coronary artery bypass graft trial. Atherosclerosis. 1999;146:369-379. UI: [underlined: 10532693]. [pmid: 10532693].
29 Carmena R, Roederer G, Mailloux H, Lussier-Cacan S, Davignon J. The response to lovastatin treatment in patients with heterozygous familial hypercholesterolemia is modulated by apolipoprotein E polymorphism. Metabolism. 1993;42:895-901. UI: [underlined: 8345800]. [pmid: 8345800].
30 Dergunov AD, Perova NV, Visvikis S, Siest G. Time-dependent lipid response on fluvastatin therapy of patients with hypercholesterolemia sensitive to apoE phenotype. Vascul Pharmacol. 2003;40:237-245. UI: [underlined: 15259790]. [pmid: 15259790].
31 Kobayashi T, Homma Y. Effects of low-dose pravastatin on plasma levels of lipids and apolipoproteins in Japanese type II hyperlipoproteinemic subjects with apolipoprotein E phenotype E3/2, E3/3, and E4/3. J Clin Pharmacol. 2001;41:1055-1058. UI: [underlined: 11583472]. [pmid: 11583472].
32 O'Malley JP, Illingworth DR. The influence of apolipoprotein E phenotype on the response to lovastatin therapy in patients with heterozygous familial hypercholesterolemia. Metabolism. 1990;39:150-154. UI: [underlined: 2299987]. [pmid: 2299987].
33 Zuccaro P, Mombelli G, Calabresi L, Baldassarre D, Palmi I, Sirtori CR. Tolerability of statins is not linked to CYP450 polymorphisms, but reduced CYP2D6 metabolism improves cholesteraemic response to simvastatin and fluvastatin. Pharmacol Res. 2007;55:310-317. UI: [underlined: 17289397]. [pmid: 17289397].
34 Rustemeijer C, Schouten JA, Voerman HJ, Beynen AC, Donker AJ, Heine RJ. Is pseudocholinesterase activity related to markers of triacylglycerol synthesis in Type II diabetes mellitus?. Clin Sci (Lond). 2001;101:29-35. UI: [underlined: 11410111]. [pmid: 11410111].
35 Berglund L, Wiklund O, Eggertsen G, et al. Apolipoprotein E phenotypes in familial hypercholesterolaemia: importance for expression of disease and response to therapy. J Intern Med. 1993;233:173-178. UI: [underlined: 8433078]. [pmid: 8433078].
36 Chaves FJ, Real JT, Garcia-Garcia AB, et al. Genetic diagnosis of familial hypercholesterolemia in a South European outbreed population: influence of low-density lipoprotein (LDL) receptor gene mutations on treatment response to simvastatin in total, LDL, and high-density lipoprotein cholesterol. J Clin Endocrinol Metab. 2001;86:4926-4932. UI: [underlined: 11600564]. [pmid: 11600564].
37 Leitersdorf E, Eisenberg S, Eliav O, et al. Genetic determinants of responsiveness to the HMG-CoA reductase inhibitor fluvastatin in patients with molecularly defined heterozygous familial hypercholesterolemia. Circulation. 1993;87:III35-III44. UI: [underlined: 8462179]. [pmid: 8462179].
38 Nestel P, Simons L, Barter P, et al. A comparative study of the efficacy of simvastatin and gemfibrozil in combined hyperlipoproteinemia: prediction of response by baseline lipids, apo E genotype, lipoprotein(a) and insulin. Atherosclerosis. 1997;129:231-239. UI: [underlined: 9105566]. [pmid: 9105566].
39 O'Neill FH, Patel DD, Knight BL, et al. Determinants of variable response to statin treatment in patients with refractory familial hypercholesterolemia. Arterioscler Thromb Vasc Biol. 2001;21:832-837. UI: [underlined: 11348882]. [pmid: 11348882].
40 Woo D, Kissela BM, Khoury JC, et al. Hypercholesterolemia, HMG-CoA reductase inhibitors, and risk of intracerebral hemorrhage: a case-control study. Stroke. 2004;35:1360-1364. UI: [underlined: 15087556]. [pmid: 15087556].
41 Vega GL, Weiner M, Kolsch H, et al. The effects of gender and CYP46 and apo E polymorphism on 24S-hydroxycholesterol levels in Alzheimer's patients treated with statins. Curr Alzheimer Res. 2004;1:71-77. UI: [underlined: 15975088]. [pmid: 15975088].
42 Leren TP, Hjermann I. Is responsiveness to lovastatin in familial hypercholesterolaemia heterozygotes influenced by the specific mutation in the low-density lipoprotein receptor gene?. Eur J Clin Invest. 1995;25:967-973. UI: [underlined: 8719939]. [pmid: 8719939].
43 Chasman DI, Posada D, Subrahmanyan L, Cook NR, Stanton VP Jr, Ridker PM. Pharmacogenetic study of statin therapy and cholesterol reduction. JAMA. 2004;291:2821-2827. UI: [underlined: 15199031]. [pmid: 15199031].
44 Thompson JF, Man M, Johnson KJ, et al. An association study of 43 SNPs in 16 candidate genes with atorvastatin response. Pharmacogenomics J. 2005;5:352-358. UI: [underlined: 16103896]. [pmid: 16103896].
45 Obayashi K, Nakamura K, Kawana J, et al. VKORC1 gene variations are the major contributors of variation in warfarin dose in Japanese patients. Clinical Pharmacology & Therapeutics. 2006;80:169-178. UI: 16890578. [pmid: 16890578].
46 Mushiroda T, Ohnishi Y, Saito S, et al. Association of VKORC1 and CYP2C9 polymorphisms with warfarin dose requirements in Japanese patients. Journal of Human Genetics. 2006;51:249-253. UI: 16432637. [pmid: 16432637].
47 Moridani M, Fu L, Selby R, et al. Frequency of CYP2C9 polymorphisms affecting warfarin metabolism in a large anticoagulant clinic cohort. Clinical Biochemistry. 2006;39:606-612. UI: 16630605. [pmid: 16630605].
48 Veenstra DL, You JH, Rieder MJ, et al. Association of Vitamin K epoxide reductase complex 1 (VKORC1) variants with warfarin dose in a Hong Kong Chinese patient population. Pharmacogenetics & Genomics. 2005;15:687-691. UI: 16141794. [pmid: 16141794].
49 Herman D, Locatelli I, Grabnar I, et al. Influence of CYP2C9 polymorphisms, demographic factors and concomitant drug therapy on warfarin metabolism and maintenance dose. Pharmacogenomics Journal. 2005;5:193-202. UI: 15824753. [pmid: 15824753].
50 Tabrizi AR, Zehnbauer BA, Borecki IB, McGrath SD, Buchman TG, Freeman BD. The frequency and effects of cytochrome P450 (CYP) 2C9 polymorphisms in patients receiving warfarin. Journal of the American College of Surgeons. 2002;194:267-273. UI: 11893129. [pmid: 11893129].
51 Scordo MG, Pengo V, Spina E, Dahl ML, Gusella M, Padrini R. Influence of CYP2C9 and CYP2C19 genetic polymorphisms on warfarin maintenance dose and metabolic clearance. Clinical Pharmacology & Therapeutics. 2002;72:702-710. UI: 12496751. [pmid: 12496751].
52 Loebstein R, Yonath H, Peleg D, et al. Interindividual variability in sensitivity to warfarin--Nature or nurture?. Clinical Pharmacology & Therapeutics. 2001;70:159-164. UI: 11503010. [pmid: 11503010].
53 Freeman BD, Zehnbauer BA, McGrath S, Borecki I, Buchman TG. Cytochrome P450 polymorphisms are associated with reduced warfarin dose.[see comment]. Surgery. 2000;128:281-285. UI: 10923005. [pmid: 10923005].
54 Furuya H, Fernandez-Salguero P, Gregory W, et al. Genetic polymorphism of CYP2C9 and its effect on warfarin maintenance dose requirement in patients undergoing anticoagulation therapy. Pharmacogenetics. 1995;5:389-392. UI: 8747411. [pmid: 8747411].
55 Chern HD, Ueng TH, Fu YP, Cheng CW. CYP2C9 polymorphism and warfarin sensitivity in Taiwan Chinese. Clinica Chimica Acta. 2006;367:108-113. UI: 16413010.
56 Kamali F, Khan TI, King BP, et al. Contribution of age, and body size, and CYP2C9 genotype to anticoagulant response to warfarin. Clinical Pharmacology & Therapeutics. 2004;75:204-212. UI: 15001972. [pmid: 15001972].
57 Linder MW, Looney S, Adams JE III, et al. Warfarin dose adjustments based on CYP2C9 genetic polymorphisms. Journal of Thrombosis & Thrombolysis. 2002;14:227-232. UI: 12913403. [pmid: 12913403].
58 Takahashi H, Wilkinson GR, Nutescu EA, et al. Different contributions of polymorphisms in VKORC1 and CYP2C9 to intra- and interpopulation differences in maintenance dose of warfarin in Japanese, Caucasians and African-Americans. Pharmacogenetics & Genomics. 2006;16:101-110. UI: 16424822. [pmid: 16424822].
59 Hillman MA, Wilke RA, Caldwell MD, Berg RL, Glurich I, Burmester JK. Relative impact of covariates in prescribing warfarin according to CYP2C9 genotype. Pharmacogenetics. 2004;14:539-547. UI: 15284536. [pmid: 15284536].
60 Higashi MK, Veenstra DL, Kondo LM, et al. Association between CYP2C9 genetic variants and anticoagulation-related outcomes during warfarin therapy. JAMA. 2002;287:1690-1698. UI: 11926893. [pmid: 11926893].
61 Lindh JD, Lundgren S, Holm L, Alfredsson L, Rane A. Several-fold increase in risk of overanticoagulation by CYP2C9 mutations. Clinical Pharmacology & Therapeutics. 2005;78:540-550. UI: 16321620. [pmid: 16321620].
62 Margaglione M, Colaizzo D, D'Andrea G, et al. Genetic modulation of oral anticoagulation with warfarin. Thrombosis & Haemostasis. 2000;84:775-778. UI: 11127854. [pmid: 11127854].
63 Aithal GP, Day CP, Kesteven PJ, Daly AK. Association of polymorphisms in the cytochrome P450 CYP2C9 with warfarin dose requirement and risk of bleeding complications.[see comment]. Lancet. 1999;353:717-719. UI: 10073515. [pmid: 10073515].
64 Peyvandi F, Spreafico M, Siboni SM, Moia M, Mannucci PM. CYP2C9 genotypes and dose requirements during the induction phase of oral anticoagulant therapy. Clinical Pharmacology & Therapeutics. 2004;75:198-203. UI: 15001971. [pmid: 15001971].
65 Pchelina SN, Sirotkina OV, Taraskina AE, Vavilova TV, Shwarzman AL, Schwartz EI. The frequency of cytochrome P450 2C9 genetic variants in the Russian population and their associations with individual sensitivity to warfarin therapy. Thrombosis Research. 2005;115:199-203. UI: 15617742. [pmid: 15617742].
66 Hillman MA, Wilke RA, Yale SH, et al. A prospective, randomized pilot trial of model-based warfarin dose initiation using CYP2C9 genotype and clinical data. Clinical Medicine & Research. 2005;3:137-145. UI: 16160068. [pmid: 16160068].
67 Ogg MS, Brennan P, Meade T, Humphries SE. CYP2C9*3 allelic variant and bleeding complications. Lancet. 1999;354:1124. UI: [underlined: 10509530]. [pmid: 10509530].
68 Topic E, Stefanovi M, Samardzija M. Association between the CYP2C9 polymorphism and the drug metabolism phenotype. Clinical Chemistry & Laboratory Medicine. 2004;42:72-78. UI: 15061384. [pmid: 15061384].
69 Voora D, Eby C, Linder MW, et al. Prospective dosing of warfarin based on cytochrome P-450 2C9 genotype. Thrombosis & Haemostasis. 2005;93:700-705. UI: 15841315. [pmid: 15841315].
70 Veenstra DL, Blough DK, Higashi MK, et al. CYP2C9 haplotype structure in European American warfarin patients and association with clinical outcomes. Clinical Pharmacology & Therapeutics. 2005;77:353-364. UI: 15900281. [pmid: 15900281].
71 Taube J, Halsall D, Baglin T. Influence of cytochrome P-450 CYP2C9 polymorphisms on warfarin sensitivity and risk of over-anticoagulation in patients on long-term treatment. Blood. 2000;96:1816-1819. UI: 10961881. [pmid: 10961881].
72 D'Andrea G, D'Ambrosio RL, Di PP, et al. A polymorphism in the VKORC1 gene is associated with an interindividual variability in the dose-anticoagulant effect of warfarin. Blood. 2005;105:645-649. UI: 15358623. [pmid: 15358623].
73 Rieder MJ, Reiner AP, Gage BF, et al. Effect of VKORC1 haplotypes on transcriptional regulation and warfarin dose. New England Journal of Medicine. 2005;352:2285-2293. UI: 15930419. [pmid: 15930419].
74 Sconce EA, Khan TI, Wynne HA, et al. The impact of CYP2C9 and VKORC1 genetic polymorphism and patient characteristics upon warfarin dose requirements: proposal for a new dosing regimen. Blood. 2005;106:2329-2333. UI: 15947090. [pmid: 15947090].
75 Vecsler M, Loebstein R, Almog S, et al. Combined genetic profiles of components and regulators of the vitamin K-dependent gamma-carboxylation system affect individual sensitivity to warfarin. Thrombosis & Haemostasis. 2006;95:205-211. UI: 16493479. [pmid: 16493479].
76 Wadelius M, Chen LY, Downes K, et al. Common VKORC1 and GGCX polymorphisms associated with warfarin dose. Pharmacogenomics J. 2005;5:262-270. UI: [underlined: 15883587]. [pmid: 15883587].
77 Aquilante CL, Langaee TY, Lopez LM, et al. Influence of coagulation factor, vitamin K epoxide reductase complex subunit 1, and cytochrome P450 2C9 gene polymorphisms on warfarin dose requirements. Clin Pharmacol Ther. 2006;79:291-302. UI: [underlined: 16580898]. [pmid: 16580898].
78 Carlquist JF, Horne BD, Muhlestein JB, et al. Genotypes of the cytochrome p450 isoform, CYP2C9, and the vitamin K epoxide reductase complex subunit 1 conjointly determine stable warfarin dose: a prospective study. J Thromb Thrombolysis. 2006;22:191-197. UI: [underlined: 17111199]. [pmid: 17111199].
79 Herman D, Peternel P, Stegnar M, Breskvar K, Dolzan V. The influence of sequence variations in factor VII, gamma-glutamyl carboxylase and vitamin K epoxide reductase complex genes on warfarin dose requirement. Thrombosis & Haemostasis. 2006;95:782-787. UI: 16676068. [pmid: 16676068].
80 Li T, Lange LA, Li X, et al. Polymorphisms in the VKORC1 gene are strongly associated with warfarin dosage requirements in patients receiving anticoagulation. Journal of Medical Genetics. 2006;43:740-744. UI: 16611750. [pmid: 16611750].
81 Osman A, Enstrom C, Arbring K, Soderkvist P, Lindahl TL. Main haplotypes and mutational analysis of vitamin K epoxide reductase (VKORC1) in a Swedish population: a retrospective analysis of case records. Journal of Thrombosis & Haemostasis. 2006;4:1723-1729. UI: 16879214. [pmid: 16879214].
82 Schelleman H, Chen Z, Kealey C, et al. Warfarin response and vitamin K epoxide reductase complex 1 in African Americans and Caucasians. Clinical Pharmacology & Therapeutics. 2007;81:742-747. UI: 17329985. [pmid: 17329985].
83 Yuan HY, Chen JJ, Lee MT, et al. A novel functional VKORC1 promoter polymorphism is associated with inter-individual and interethnic differences in warfarin sensitivity. Human Molecular Genetics. 2005;14:1745-1751. UI: 15888487. [pmid: 15888487].
84 Tham LS, Goh BC, Nafziger A, et al. A warfarin-dosing model in Asians that uses single-nucleotide polymorphisms in vitamin K epoxide reductase complex and cytochrome P450 2C9. Clin Pharmacol Ther. 2006;80:346-355. UI: [underlined: 17015052]. [pmid: 17015052].
85 Obayashi K, Nakamura K, Kawana J, et al. VKORC1 gene variations are the major contributors of variation in warfarin dose in Japanese patients. Clinical Pharmacology & Therapeutics. 2006;80:169-178. UI: 16890578. [pmid: 16890578].
86 Kimura R, Miyashita K, Kokubo Y, et al. Genotypes of vitamin K epoxide reductase, gamma-glutamyl carboxylase, and cytochrome P450 2C9 as determinants of daily warfarin dose in Japanese patients. Thromb Res. 2007;120:181-186. UI: [underlined: 17049586]. [pmid: 17049586].
87 Terrazzino S, Agostini M, Pucciarelli S, et al. A haplotype of the methylenetetrahydrofolate reductase gene predicts poor tumor response in rectal cancer patients receiving preoperative chemoradiation. Pharmacogenetics & Genomics. 2006;16:817-824. UI: 17047490. [pmid: 17047490].
88 Suh KW, Kim JH, Kim dY, Kim YB, Lee C, Choi S. Which gene is a dominant predictor of response during FOLFOX chemotherapy for the treatment of metastatic colorectal cancer, the MTHFR or XRCC1 gene?. Annals of Surgical Oncology. 2006;13:1379-1385. UI: 17009149. [pmid: 17009149].
89 Ott K, Vogelsang H, Marton N, et al. The thymidylate synthase tandem repeat promoter polymorphism: A predictor for tumor-related survival in neoadjuvant treated locally advanced gastric cancer. International Journal of Cancer. 2006;119:2885-2894. UI: 16929515.
90 Chung HH, Kim MK, Kim JW, et al. XRCC1 R399Q polymorphism is associated with response to platinum-based neoadjuvant chemotherapy in bulky cervical cancer. Gynecologic Oncology. 2006;103:1031-1037. UI: 16875718. [pmid: 16875718].
91 Wu X, Gu J, Wu TT, et al. Genetic variations in radiation and chemotherapy drug action pathways predict clinical outcomes in esophageal cancer. Journal of Clinical Oncology. 2006;24:3789-3798. UI: 16785472. [pmid: 16785472].
92 Ruzzo A, Graziano F, Kawakami K, et al. Pharmacogenetic profiling and clinical outcome of patients with advanced gastric cancer treated with palliative chemotherapy. Journal of Clinical Oncology. 2006;24:1883-1891. UI: 16622263. [pmid: 16622263].
93 Sarbia M, Stahl M, von WC, Weirich G, Puhringer-Oppermann F. The prognostic significance of genetic polymorphisms (Methylenetetrahydrofolate Reductase C677T, Methionine Synthase A2756G, Thymidilate Synthase tandem repeat polymorphism) in multimodally treated oesophageal squamous cell carcinoma. British Journal of Cancer. 2006;94:203-207. UI: 16333305. [pmid: 16333305].
94 Jakobsen A, Nielsen JN, Gyldenkerne N, Lindeberg J. Thymidylate synthase and methylenetetrahydrofolate reductase gene polymorphism in normal tissue as predictors of fluorouracil sensitivity.[see comment]. Journal of Clinical Oncology. 2005;23:1365-1369. UI: 15735113. [pmid: 15735113].
95 Etienne MC, Formento JL, Chazal M, et al. Methylenetetrahydrofolate reductase gene polymorphisms and response to fluorouracil-based treatment in advanced colorectal cancer patients. Pharmacogenetics. 2004;14:785-792. UI: 15608557. [pmid: 15608557].
96 Cohen V, Panet-Raymond V, Sabbaghian N, Morin I, Batist G, Rozen R. Methylenetetrahydrofolate reductase polymorphism in advanced colorectal cancer: a novel genomic predictor of clinical response to fluoropyrimidine-based chemotherapy. Clinical Cancer Research. 2003;9:1611-1615. UI: 12738713. [pmid: 12738713].
97 Marcuello E, Altes A, Menoyo A, Rio ED, Baiget M. Methylenetetrahydrofolate reductase gene polymorphisms: genomic predictors of clinical response to fluoropyrimidine-based chemotherapy?. Cancer Chemotherapy & Pharmacology. 2006;57:835-840. UI: 16187112. [pmid: 16187112].
98 Anderson JL, Horne BD, Stevens SM, et al. Randomized trial of genotype-guided versus standard warfarin dosing in patients initiating oral anticoagulation. Circulation. 2007;116:2563-2570. UI: 17989110. [pmid: 17989110].
99 Caraco Y, Blotnick S, Muszkat M. CYP2C9 genotype-guided warfarin prescribing enhances the efficacy and safety of anticoagulation: a prospective randomized controlled study. Clinical Pharmacology & Therapeutics. 2008;83:460-470. UI: 17851566. [pmid: 17851566].