# Search strategies, flow chart of included studies, and template of extraction forms

## CYP2C9 or VKORC1 and warfarin

(CYP2C9.mp. OR VKORC1.mp.OR *Mixed Function Oxygenases/ge OR *Mixed Function Oxygenases/me) AND (Warfarin.mp. or exp Warfarin/)

Figure 1 Flow diagram of eligible studies of CYP2C9, VKORC1 and warfarin

### Apo E genotype and response to statin treatment

Search terms included (Apolipoprotein-E OR APOE OR APOE2 OR APOE3 OR APOE4) AND (statin OR hydroxymethylglutaryl-CoA reductase inhibitors OR lovastatin OR atorvastatin OR simvastatin OR pravastatin OR rosuvastatin OR fluvastatin).

Figure 2 Flow diagram of eligible studies of ApoE genotypes and statin therapy

### MTHFR and Chemotherapy

Search terms included (methylenetetrahydrofolate reductase OR MTHFR) AND (gene OR polymorphism) AND chemotherapy.

Figure 3 Flow diagram of eligible studies of MTHFR genotype and response to chemotherapy

Appendix 1. Table 1 CYP2C9/VKORC1 with warfarin therapy

Study
- First author:; - Year; - Country:; - Journal; - Study Design; - Duration of follow up
Outcomes assessed (yes/no)
- Time to achieve stable dose; - Overcoagulation / proportion high INR; - Time to first over the ceiling INR; - Serious or life threatening bleeding event; - Intensity of followup; - Change in management
Cohort characteristics
- Number of patients:; - Male/Female; - Male %; - Racial descent:; - Age (y):; - Inclusion criteria defefined; - Criteria of Diagnosis; - Type of Diseases; - Disease Duration; - Duration of follow-up; - Exclusion criteria defined
Intervention Used
- Type of warfarin; - Dosage of warfarin; - Duration of treatment; - Concomittant therapy; - Number of patients excluded
Patient characteristics in the cohort (percentage)
- Cohort medications; - Co medications
Study Results
- Genotype distribution; - Sex-specific; - Gene-gene interactions; - Gene-environment interactions; - VKORC1 methodology; - CYP2C9 methodology; - Was the genotype methodology replicated with; - another protocol; - Blindness of genotyping:; - Is data by gender provided?; - Power calculations provided?; - Cohort overlapping with previous studies; - How were cases recruited?; - Is HWE assessed?; - Predictor analyses controlled for other risk factors

Appendix1. Table 2 Extracted data from each study of ApoE with statin therapy

Study
- First author; - Year; - Country; - Journal; - Study design; - Duration of follow up
Outcomes assesed (yes/no)
- LR; - TC; - LDL; - HDL; - TGs; - APoA1; - ApoB; - ApoE; - ApoA2; - ApoCII; - CRP; - CETP activity; - PLTP activity; - Non-HDLC; - Pche activity; - LP(a); - CVER; - Mortality; - Clinical events^*^; - Intracerebral hemorrhage (ICH); - ADR; - angiographical change of CAD; - ARR; - Discontinuation of statins
Cohort characteristics
- Number of patients; - Male/Female; - Racial descent; - Age; - Inclusion criteria defined; - Criteria of Diagnosis; - Type of Disease; - Disease duration; - Duration of Follow-up; - Age at onset; - Exclusion criteria defined
Patient characteristics in the cohort (percentage)
- Hyperlipidemics; - severe or mild hyperipidemia; - Primary or secondary hyperlipidemia; - Familial Hyperlipidemia; - Diabetics; - Hypertensives; - CAD; - Alcoholics (never/ever); - Smoking (never/ever)
Intervention used
- Hypolipidemic diet:; - Type of statin:; - Dosage of statin:; - Duration of treatment:; - Concomittant therapy:; - Number of patients excluded because of SE:
Study Results
- Genotype distribution; - LR: Means of individual percentage change in lipid/lipoprotein/biochemical parameter following treatment with statins per genotype; - CADR: percentage of patients with angiographical change (progression/regression) of CAD lesions following treatment with statins per genotype; - CVER: percentage of new cardiovascular events following treatment with statins per genotype; - Mortality estimates following treatment with statins per genotype; - ARR: Percentage of patients dicsontinuating statin treatment per genotype; - Percentage of statin related side-effects per genotype; - Gender interaction; - Gene-gene interactions; - Genetic contrasts used; - Baseline differences in lipid profile according to genotype; - Gene-dose effect assesed

* Definition of Clinical events by individual studies.

Appendix 1.Table 3 Extracted data from each study for MTHFR polymorphisms and response to chemotherapy

Study
- First author; - Year; - Country; - Journal; - Study design
Cohort characteristics
- Number of patients; - Male/Female; - Racial descent; - Age; - Inclusion criteria defined; - Criteria of Diagnosis; - Disease duration; - Survival time; - Exclusion criteria defined
Type of cancer or malignancy MTHFR gene polymorphism studied Tumor grade and stage Clinical Outcomes investigated Intervention used
- Type of chemotherapy; - Dosage scheme:
Definition of responders and non-responders Patient comorbitidy Study Results
- Genotype distribution; - Gender interaction; - Age interactions; - Genetic contrasts used