# Apo E gene polymorphisms and response to statin therapy

## Background

The Apo E gene is located on human chromosome 19. The primary product of the Apo E gene is a 317-amino acid protein that gives rise to the 299-amino acid mature protein by cleavage of an 18-amino acid signal peptide.74 The primary role of Apo E in plasma lipid metabolism is to mediate the interaction of chylomicron remnants and intermediate-density lipoprotein particles with lipoprotein receptors, including the low-density lipoprotein (LDL) receptor and the chylomicron remnant or Apo E receptor.

Three major Apo E isoforms are coded by three alleles at the Apo E gene, designated as e2, e3, and e4 (dbSNP accession numbers rs7412 and rs429358). In the general population, e2 carriers are consistently associated with lower levels of total cholesterol (TC), LDL cholesterol, and elevated levels of triglyceride (TG) than are e3 carriers. Conversely, e4 carriers are associated with higher levels of total and LDL cholesterol. In general, the lower TC levels in e2 carriers are associated with reduced coronary and peripheral artery atherosclerosis, and the higher cholesterol levels in e4 carriers are associated with a higher prevalence of cardiovascular disease (CVD).75,76

Statins are competitive inhibitors of 3-hydroxy-3-methylglutaryl coenzyme A (HMG-CoA) reductase, a rate-limiting enzyme in the cholesterol biosynthesis pathway.77 Inhibition of cholesterol biosynthesis reduces secretion of Apo B-containing lipoproteins from the liver and up-regulates LDL receptor activity, both of which contribute to LDL-C lowering in the plasma.78

The inter-individual variation in lipid response to statin therapy is considerable, in terms of reduced LDL levels and clinical outcomes. This variability has been attributed to individual environmental or genetic factors.79,80 The most studied genetic variation is the Apo E polymorphism and its association with reductions in LDL levels with statin therapy.80–82

One meta-analysis of five studies83 investigated differences in the lipid response to statins with genetic variation. In that study, LDL-C was lowered more in e2 carriers (37%, P< 0.05) than in e3 homozygotes and e4 carriers (35%, 33%, respectively).

### Data Synthesis and Analysis for the association of Apo E gene and statin therapy

Studies provide data on lipid level (mean [SD]) in e2 carriers (e2e2+e2e3), e3 homozygotes (e3e3), and e4 carriers (e3e4+e4e4). Among the studies we evaluated, e2e4 data were not reported. Studies compared these three groups (e2 carriers, e3 homozygotes, and e4 carriers).

We calculated the change in lipid levels as percent improvement (or decline) from baseline for each genotype within a study with the formula: [(final value − baseline value)/baseline value]×100%]. We performed meta-analyses on the percent change in lipid levels (Δμ, (95% CI)) for e2 carriers, e3 homozygotes, and e4 carriers using the inverse of the variance of Δμ as a weighting factor.

Overall, for each outcome, the genotypes were compared (e2 carriers, vs. e3 homozygotes and e4 carriers vs. e3 homozygotes) using a general linear model under a random-effects assumption and the inverse of the variance of Δμ as a weighting factor. Because the data in individual studies were based on carrier contrasts but were not homogeneous with respect to allelic contrasts, these differences were evaluated quantitatively with point estimates of summary Δμ. Thus, results for carrier contrasts should be interpreted with caution. In subgroups, the genotypes were compared with z scores because the number of studies was limited. Significance levels for the comparisons (Pc-value) were adjusted using Bonferroni’s correction. Differences in subgroups of genotypes were also evaluated quantitatively on the basis of the point estimates of summary Δμ to investigate possible trends.

For key question 2, concerning the effect of the APO E genotype on statin response in particular subpopulations, subgroup and sensitivity analyses for potential effect modifiers were performed for the following three categories:

1. Patient-related factors, including analyses for sex and ethnicity
2. Disease-related factors, including analyses for studies with and without diabetic patients and studies with and without familial hyperlipidemia.
3. Study design-related factors, including analyses for the duration of follow up (short ≤12 weeks versus long >12 weeks), and type and dosage of statin.

### Results for Section 2: Apo E and Response to Statin Therapy

#### Eligible studies

Of 262 studies, 44 met the inclusion criteria for a systematic review of Apo E genotype association with statin therapy.53,83–125 The studies were published between 1999 and 2007. Of the 44 published articles, 21 53,83,85,91,95,100,101,107,112–114,116,118,122,124,125 provided quantitative data for genotypes and outcomes and were included in our meta-analyses. Appendix 1 presents a flow chart of retrieved and excluded studies, with the reasons for exclusion.

The study and population characteristics are summarized in Table 3.1 and detailed in Appendix 2.

Table 3.1 Characteristics of studies testing for associations between the ApoE genotype and response to statin therapy

Characteristics | Description: number of studies (references)
Study design | Cohort studies: 35 53,83–86,88–92,95–97,99–107,109–116,118–122,124 of which 14 studies were from randomized control trial-arm study 83–85,88,90,96,97,99,104,107,112,113,119,121 Cross-sectional: 2 108,123 Retrospective studies: 5 87,93,98,117,125
Ethnicity/Descent | Caucasians: 32 53,86–92,94–99,101–115,119,121,125 Asians: 5 100,117,122,124,126 Jewish: 1 102 Mixed: 3 85,120,123 Not documented: 2 83,84
Data on Sex | Men: 9 87,91,92,99,106,107,110,113,114 Women: 5 87,91,110,113,114
Outcomes assessed: | CV events; - Mortality: 2 97,105; - Clinical events: 3 85,97,105; - Intracranial hemorrhage: 1 123; CAD response; - Angiographical change of CAD: 85,107; Lipid response; - Total cholesterol (TC): 30 53,83–89,92,93,95,96,98–101,103,107–109,112–114,116–119,122,124,125; - Low density lipoprotein (LDL): 36 53,83–93,95,96,98–103,107,108,110–114,116–119,121,122,124,125; - High density lipoprotein (HDL): 26 53,83–85,87,88,90–92,95,96,99–101,107–110,112–114,116,118,119,122,125; - Triglyceride (TG): 28 53,83–87,91–93,95,96,99–101,107–110,112–116,118,119,122,124,125; - Apolipoprotein (ApoA1): 7 53,84,100,101,108,116,122; - Apolipoprotein (Apo B): 10 53,84,86,89,100,103,108,116,122,124; - Apolipoprotein E (Apo E): 4 53,86,100,122; - Apolipoprotein (ApoA2): 1 116; - Apolipoprotein (ApoCII): 2 84,122; - C-reactive protein (CRP): 1 94; - Cholesteryl ester transfer protein (CETP) activity: 1 101; - Plasma phospholipid transfer protein (PLTP) activity: 1 104; - Non-HDLC: 1 120; - Pseudocholinesterase (Pche) activity: 1 115; - Lipoprotein a (LP(a)): 1 84; Adverse reactions response; - Discontinuation of statins: 1 106
Type of Hyperlipidemia | Familial: 12 53,86,87,89–91,98,102,103,110,111,121 Non-Familial: 33 53,83–85,88,92–97,99–101,104,106–109,111–120,122–125
Presence of Diabetes Mellitus: | Diabetic cohort: 4 104,115,118,122 Diabetic patients excluded from study: 15 83,85,87,91,95,100,101,107,110,112–114,116,124,125
Type of statin | Pravastatin: 8 83,86,92,107,114,115,117,122 Simavastatin: 10 89–91,95,97,98,109,118,121,124 Atorvastatin: 6 53,87,96,99,104,113 Lovastatin: 8 84,87,101,103,110,112,116,118 Fluvastatin: 3 85,92,102 Not documented: 7 93,94,106,108,120,123,125
Duration of follow-up | Short (≤12 weeks): 23 85–87,89–93,98,100,101,103,109–112,115,116,118–122,124 Long (>12 weeks): 16 53,83–85,88,95–97,99,102,104,107,108,113,114,117

## Results

### Key Question #1 Among patients taking statin therapy, is there any association between carrying the Apo E genotype and clinical outcomes, such as cardiovascular events, mortality, or other composite clinical endpoint?

#### Coronary artery disease response

Two studies evaluated the association of Apo E polymorphisms on angiographic progression or regression of CAD among patients treated with statins.85,107 Both studies reported no significant treatment–genotype interaction between Apo E genotype and statin therapy with respect to progression or regression of CAD. However, a small angiographic benefit in e2 carriers was noted in both studies.

#### Mortality

Two studies evaluated the association of Apo E polymorphisms on mortality among patients treated with statins.97,105 In a substudy of the Scandinavian Simvastatin Survival Study (the 4S study),97 during the follow-up of myocardial infarction (MI) survivors, treatment with simvastatin reduced the number of deaths in 187 e4 carriers from 15.7% to 6.0%, and decreased mortality risk by 0.33 (95% CI 0.16 to 0.69). In 301 non-e4 carriers, simvastatin also decreased mortality from 9.0% to 5.1%, and decreased mortality risk to 0.66 (95% CI, 0.35 to 1.24). In the same study, 166 placebo-treated e4 carriers had almost twice the mortality risk as that of 312 non-carriers (15.7% and 9%; RR 1.8, 95% CI: 1.1 to 3.1). The Kaplan-Meier curves for all-cause mortality for both simvastatin treated e4 carriers and non-carriers were similar, suggesting that simvastatin negated the increased risk associated with e4 carrier status. However, in the Rotterdam study for all the Apo E genotypes, the relative risk of all-cause mortality in patients with and without statin treatment was similar.105

#### Composite clinical events

Three studies examined the effect of Apo E polymorphisms on the composite endpoint of “clinical events” in patients treated with statins.85,97,105 The definition of “clinical events” varied among studies. Gerdes defined clinical events as “coronary death, nonfatal definite or probable MI, silent MI, or resuscitated cardiac arrest;”97 Ballantyne described them as “percutaneous transluminal coronary angioplasty, coronary artery bypass grafting, definite or probable MI, unstable angina, death from any cause;” 85 and Maitland van der Zee defined it as MI, stroke, or death. 105 The genotypes did not differ in the rate of composite clinical events in any of the three studies.

#### Intracerebral Hemorrhage

In one study, among 78 patients treated with statins, e3e3 homozygotes had a lower risk for intracerebral hemorrhage (OR 0.08, 95% CI 0.02 to 0.39) than did the 40 e2 and e4 carriers (OR 0.69, 95% 0.29 to 1.78).123

### Key Question #1 Among patients taking statin therapy, is there any association between carrying the Apo E genotype and biochemical variables, such as total, LDL, or HDL cholesterol or triglyceride levels?

#### Total cholesterol

All 30 studies evaluating the association of Apo E genotype with total cholesterol (TC) levels in patients treated with statins 53,83–89,92,93,95,96,98–101,103,106,107,109,112–114,116–119,122,124,125 reported that statins significantly lowered TC levels in e2 carriers, e3e3 homozygotes, and e4 carriers. However, 21 of these studies found no significant differences between the groups in the amount of reduction among genotypic groups .53,83,84,86,89,91,92,95,96,98,99,101,104,106,112 114,116,117,122,124,125 Four studies reported that e2 carriers had significantly greater reductions in TC levels from baseline than did other genotypes, 100,107,109,113 three studies reported that e4 carriers had significantly smaller reductions of TC levels, 85,92,111 and only one study reported that e4 carriers had greater reductions in TC than e2 carriers.118 Eighteen studies that provided quantitative data were included in the meta-analysis. 53,83,85,91,95,100,101,107,112–114,116,118,122,124,125

The meta-analysis included 2,848 patients from studies with different designs, thus comprising a non-homogeneous study group. The meta-analysis for e2-carriers, e3 homozygotes, and e4-carriers showed that between-study heterogeneity was significant (P_Q_ < 0.10, I^2^ ≥ 75%). In the main analysis, the pooled change in TC from baseline was significant (Δμ = −27.7% (−32.5% to −22.8%), Δμ = −25.3% (−28.0% to −22.6%) and Δμ = −25.1% (−29.3% to −21.0%), respectively (Table 3.2; Figure 3.1–3.3).

Overall, there was no statistical difference between the genotypes (P ≥ 0.05), although e2 carriers had a better response, followed by e3 homozygotes and e4 carriers. In addition, the confidence intervals of the three genotypes overlapped, indicating a lack of significant differences.

### Key Question #2 What demographic or clinical variables mediate the association between pharmacogenomic test results and biochemical or clinical outcomes among patients taking statin therapy?

Baseline TC levels had a significant effect (P < 0.01) on the relative change in TC after statin therapy. Other possible sources of heterogeneity were explored through subgroup analyses. Subgroup analysis was also used to evaluate patient- and disease-related factors that might affect the response to Apo E. Subgroups analyzed were the type of statin, dosage, ethnicity (racial descent), sex, familial hyperlipidemia, and duration of follow-up (Table 3.2; Figure 3.1–3.3). Only familial hyperlipidemia with e4 carriers differed significantly from the other groups, having the weakest response to statin therapy.

#### Type of statin

In comparisons between genotypes, simvastatin, lovastatin, and atorvastatin were associated with a much greater lowering of TC levels than was pravastatin. In four studies that evaluated lovastatin, e2 and e4 carriers had a greater mean reduction in TC than did e3e3 homozygotes.87,101,112,116 For all the other type of statins, e2 carriers had a better response, followed by e3e3 homozygotes. On the basis of the dose of statin, five studies on pravastatin had extractable data for a meta-analysis.83,100,107,114,122

Pravastatin studies were classified as high-dose (more than 20 mg) or low-dose (20 mg or less) for analysis. With pravastatin therapy, e4 carriers had the smallest pooled reduction in TC. These results were consistent with the main analyses.

#### Ethnicity

The subgroup analysis based on the ethnicity (racial descent) showed that the reduction in TC with statin therapy among Caucasians was consistent with the main analyses.53,85,87,91,95,101,107,112–114,116,125 However, in studies conducted among Asians, e4 carriers were associated with a greater response, followed by the e2 carriers and e3 homozygotes (Table 3.2).118,122,124,125 In addition, in Asians, e2 carriers and e3e3 homozygotes had poorer responses than did Caucasians, indicating that ethnicity might mediate the association between Apo E and response to statin therapy.

#### Sex

With statin therapy, the male e2 carriers in three studies77,127,128 and the female e2 carriers in three other studies87,113,114 had a greater reduction in TC than did the opposite-sex groups. However in men, the e4 carriers had the lowest response to statin therapy, suggesting a possible sex-specific interaction between Apo E genotypes and TC response to statin therapy.

#### Familial hyperlipidemia

Three studies included in the meta-analysis were conducted in heterozygous familial hyperlipidemia patients,53,87,91 and 15 studies enrolled non-familial hyperlipidemia patients. 83,85,95,100,101,107,112–114,116,118,122,124,125 In the familial hyperlipidemia studies, the e2 allele was associated with the greatest response among the genetic subgroups. The e3e3 homozygotes had greater reductions in TC than did the e4 carriers. The mean change in TC differed moderately between genotype groups in patients with non-familial hyperlipidemia, as e2 and e4 carriers showed a slightly better response than did e3 homozygotes.

#### Duration of follow-up

The e2 carriers had a greater mean decrease in TC in studies with both short (less than 12 weeks) 85,87,91,99–101,113,116,118,122,124 and long follow-ups.53,83,95,107,114 The decrease was larger in the short follow-up studies.

The Egger test and the Begg-Mazumdar test for changes in TC among e2 carries indicated that there was no differential magnitude of effect in large versus small studies (P=0.43 and P=0.11, respectively).

Table 3.2 Results of the meta-analysis and subgroup analyses for the association between the Apo E Genotype and mean change in total cholesterol levels in patients treated with statins

Variable | Number of studies | Mean change from baseline in TC (%) for e2 carriers (95% CI) | Mean change from baseline in TC (%) for e3 homozygotes (95% CI) | Mean change from baseline in TC (%) for e4 carriers (95% CI)
Overall | 18 | −27.7 (−32.5, −22.8) | −25.3 (−28.0, −22.6) | −25.1 (−29.3, −21.0)
Pravastatin | 5 | −23.1 (−27.6, −18.6) | −19.3 (−22.3, −16.2) | −17.3 (−19.1, −15.6) (Pc<0.01)
Pravastatin high dose | 2 | −22.2 (−25.2, −19.1) | −20.3 (−23.6, −17.0) | −17.9 (−18.4, −17.4) (Pc=0.02)
Pravastatin low dose | 3 | −23.2 (−33.6, −12.9) | −18.6 (−23.8, −13.5) | −17.0 (−20.3, −13.6)
Simvastatin | 3 | −32.0 (−37.1, −26.9) | −30.3 (−34.2, −26.5) | −31.3 (−34.3, −28.3)
Lovastatin | 4 | −32.3 (−42.6, −22.0) | −30.3 (−34.7, −25.93) | −30.0 (−34.0, −26.0)
Atorvastatin | 3 | −32.8 (−40.6, −25.0) | −27.7 (−28.8, −26.6) | −26.2 (−27.5, −24.9)
Caucasians | 13 | −28.4 (−29.1, −27.6) | −26.6 (−29.8, −23.5) | −25.4 (−29.6, −21.3)
Asians | 4 | −25.5 (−32.3, −18.8) | −22.8 (−29.1, −16.6) | −25.8 (−35.2, −16.4)
Men | 3 | −31.9 (−43.9, −19.8) | −26.6 (−36.0, −17.3) | −22.1 (−29.4, −14.8)
Women | 3 | −28.2 (−42.9, −13.5) | −26.5 (−36.1, −16.7) | −26.1 (−36.6, −15.5)
Familial hyperlipidemia | 3 | −39.3 (−43.4, −35.3) | −32.8 (−37.2, −28.3) | −29.6 (−32.1, −27.1)^1^ (Pc<0.01)
Non-Familial hyperlipidemia | 15 | −24.9 (−27.2, −22.5) | −23.8 (−25.9, −21.7) | −24.3 (−28.0, −20.7)
Short follow-up | 12 | −28.3 (−34.4, −22.2) | −26.8 (−30.1, −23.5) | −26.9 (−30.7, −23.0)
Long follow-up | 5 | −24.9 (−35.8, −14.0) | −22.3 (−26.0, −18.7) | −20.8 (−25.2, −16.5)

TC = total cholesterol

1 PQ > 0.14, I^2^ < 55%; Significant and large heterogeneity (P_Q_ < 0.01, I^2^ ≥ 75%) is presented in all settings

Figure 3.1 Individual and pooled estimates of percent reductions in total cholesterol from baseline for e2-carriers treated with statins

(Data are plotted in ascending order of baseline TC level. The analysis used a random-effects model.

Figure 3.2 Individual and pooled estimates of percent reductions in total cholesterol from baseline in e3 homozygote treated with statins

(Data are plotted in ascending order of baseline TC levels. The analysis used a random-effects model.)

Figure 3.3 Individual and pooled estimates of percent reductions in total cholesterol from baseline in e4 carriers treated with statins

(Data are plotted in ascending order of baseline TC levels. The analysis used a random-effects model.)

### Key Question #1 Among patients taking statin therapy, is there any association between carrying the Apo E genotype and biochemical variables, such as total, LDL, or HDL cholesterol or triglyceride levels?

#### Low-density-lipoprotein cholesterol

Thirty-six studies investigated the LDL-cholesterol-lowering effect of statins in association with the Apo E genotype.53,83–93,95,96,98–103,107,108,110–114,116–119,121,122,124,125 All studies reported that the e2-carriers, e3e3 homozygotes, and e4-carriers had significant reductions in LDL levels compared to their baseline values. Of the 36 studies, 18 reported no significant differences in the amount of reduction of LDL levels among genotypic groups.53,83,84,86,89–92,95,96,98,110,112,114,116,122,124,125 Seven studies reported that e2 carriers had greater reductions in LDL levels than did other genotypes,90,99,100,107,111,113,121 five studies reported that e4 carriers had smaller reductions in LDL levels,85,87,93,108,117 and two studies reported that e4 carriers responded better than e2 carriers.102,118

Twenty studies were included in the meta-analysis.53,83,85,87,95,100,101,107,112–114,116,118,122,124,125 The meta-analysis for e2-carriers, e3e3 homozygotes, and e4-carriers found large heterogeneity among studies (P < 0.10, I^2^ ≥ 50%), and the pooled mean (95% CI) reduction in LDL was significantly lower for all genotypic groups; Δμ = -35.9% (−39.9% to −31.9%), Δμ = −33.6 (−36.5% to −30.8%) and Δμ = −31.8% (−35.7% to −27.9%), respectively (Table 3.3 and Figures 3.4–Figure 3.6). Significant and large heterogeneity (P_Q_ < 0.10, I^2^ ≥ 75%) was present in all or most of the settings.

Overall, there was no statistical difference between the genotypes (Pc ≥ 0.05), although e2 carriers had greater reductions, followed by the e3 homozygotes and the e4 carriers.

Table 3.3 Results of the meta-analysis and subgroup analyses for associations between the Apo E genotype and low-density lipoprotein levels in patients treated with statins

Variable | Number of studies | Mean change in LDL (%) from baseline for e2 carriers (95% CI) | Mean change in LDL (%) from baseline for e3 homozygotes (95% CI) | Mean change in LDL (%) from baseline for e4 carriers (95% CI)
Overall | 20 | −35.9 (−39.9, −31.9) | −33.6 (−36.5, −30.8) | −31.8 (−35.7, −27.9)
Pravastatin | 5 | −32.5 (−40.9, −24.1) | −27.5 (−32.0, −23.1) | −24.7 (−28.6, −20.7)
Pravastatin high dose | 2 | −32.7 (−34.6, −30.8) | −29.1 (−30.7, −27.4) (Pc < 0.02) | −26.4 (−27.3, −25.5) (Pc < 0.01)
Pravastatin low dose | 3 | −30.9 (−50.2, −11.5) | −26.9 (−35.7, −18.2) | −23.8 (−30.8, −16.9)
Simvastatin | 3 | −39.7 (−43.6, −35.9) | −38.5 (−39.9, −37.1) | −34.7 (−37.8, −31.6)
Lovastatin | 6 | −36.7 (−43.0, −30.4) | −36.7 (−41.2, −32.3) | −34.8 (−41.4, −28.3)
Atorvastatin | 3 | −41.9 (−48.1, −35.7) | −37.0 (−39.3, −34.7) | −34.1 (−35.7, −32.5)^1^(Pc=0.04)
Caucasians | 15 | −36.3 (−40.9, −31.8) | −34.4 (−37.3, −31.6) | −31.9 (−35.3, −28.6)
Asians | 4 | −35.2 (−45.8, −24.6) | −32.1 (−39.8, −24.4) | −31.9 (−37.6, −26.2)
Men | 4 | −41.1 (−44.3, −38.5) | −33.8 (−41.7, −25.9) | −30.3 (−37.0, −23.6)
Women | 4 | −38.1 (−47.2, −28.8) | −36.7 (−47.2, −26.3) | −32.1 (−41.9, −22.2)
Familial hyperlipidemia | 5 | −39.9 (−46.9, −32.9) | −36.3 (−40.0, −32.7) | −32.8 (−36.3, −29.4)
Non-Familial hyperlipidemia | 15 | −34.2 (−38.1, −30.4) | −32.7 (−35.4, −29.9) | −31.7 (−35.9, −27.6)
Short follow-up | 14 | −36.3 (−40.8, −31.8) | −35.1 (−38.3, −32.0) | −33.6 (−37.2, −30.0)
Long follow-up | 5 | −32.8 (−42.9, −22.7) | −30.3 (−35.5, −25.1) | −28.3 (−34.1, −22.5)
Diabetes | 2 | −27.8 (−34.6, −21.0)^2^ | −27.2 (−35.5, −18.9) | −37.7 (−57.1, −18.2)
No diabetes | 18 | −37.0 (−41.0, −33.0) | −34.3 (−36.9, −31.7) | −31.3 (−34.3, −28.4)

1 P_Q_ = 0.97, I^2^= 0;

2 P_Q_ = 0.98

Figure 3.4 Individual and pooled estimates of percent reduction in low-density lipoprotein from baseline in e2-carriers treated with statins

(Data are plotted in ascending order of baseline LDL levels. The analysis used a random-effects model.)

Figure 3.5 Individual and pooled estimates of percent reduction in low-density lipoprotein from baseline in e3 homozygotes treated with statins

(Data are plotted in ascending order of baseline LDL levels. The analysis used a random-effects model.)

Figure 3.6 Individual and pooled estimates of percent reduction in low-density lipoprotein from baseline in e4 carriers treated with statins

(Data are plotted in ascending order of baseline LDL levels. The analysis used a random-effects model.)

### Key Question #2 What demographic or clinical variables mediate the association between pharmacogenomic test results and biochemical or clinical outcomes among patients taking statin therapy?

Patient- and disease-related factors were analyzed for their effects on response by genotype (Table 3.3). The results were significant only for atorvastatin and high doses (>20 mg) of pravastatin.

Studies of Caucasians 53,85,87,91,95,101,107,110,112–114,116,125 had results similar to those of the overall analysis, whereas in studies of Asians100,118,122,124 pooled changes in LDL from baseline did not differ greatly among the genotypes. Subgroup analysis by sex87,91,113,114 and familial hyperlipidemia53,87,91,110 had results similar to those of the overall analysis. However, in familial hyperlipidemia studies,53,87,91,110 the mean reduction in LDL was greater than it was in the non-familial hyperlipidemia studies 83,85,95,101,107,112–114,116,118,122,124,125. In studies with both short 85,87,91,100,101,110,112,113,116,118,124 and long follow-ups,53,83,95,107,114 the e2 carriers showed greater decreases in LDL. Diabetes could be a potential source of heterogeneity. Contrary to the main analysis, e4 carriers with diabetes,118,122 had a greater response to statin therapy than did patients with other genotypes and those without diabetes.53,83,85,87,91,95,100,101,107,110,112–114,116,124,125

### Key Question #1 Among patients taking statin therapy, is there any association between carrying the Apo E genotype and biochemical variables, such as total, LDL, or HDL cholesterol or triglyceride levels?

#### High-Density Lipoprotein Cholesterol

Twenty-six studies investigated the association between the Apo E genotype with the effect of statins in increasing HDL cholesterol levels.53,83–85,87,88,91,92,95,96,99–101,107–110,112–114,116,118,119,122,125 Twenty-two studies reported that statin therapy was not associated with significant changes in HDL among Apo E genotypes.53,83,84,86,90–92,95,96,99–101,108,110,112–114,116,118,122 Three studies reported that e2 carriers responded better than other genotypes,85,107,125 and only one study reported that e4 carriers responded better than did e2 carriers.87

Twenty-one studies were included in the meta-analysis.53,83,85,87,91,95,100,101,107,108,110,112–114,118,125 The meta-analysis for e2-carriers, e3e3 homozygotes, and e4-carriers showed great heterogeneity among studies (P < 0.10, I^2^ ≥ 50%), and the pooled mean increase in HDL (95% CI) was significant: Δμ = +9.44% (3.91% to 15.0%), Δμ = +7.45% (5.59% to 9.49%) and Δμ = +7.61% (4.47% to 10.7%), respectively (Table 3.4 and Figures 3.7 – 3.9).

Although statin therapy increased HDL levels most in e2 carriers, followed by the e4 carriers and then by e3 homozygotes, the overall differences were small, and the three genotypes did not differ significantly (Pc ≥ 0.05).

Table 3.4 Results of the meta-analysis and subgroup analyses for associations between the Apo E genotype and high-density lipoprotein levels in patients treated with statins

Variable | Number of studies | Mean change in percentage HDL for e2 carriers (95% CI) | Mean change in percentage HDL for e3e3 homozygotes (95% CI) | Mean change in percentage HDL for e4 carriers (95% CI)
All | 21 | 9.44 (3.91, 15.0) | 7.45 (5.59, 9.49) | 7.61 (4.47, 10.7)
Pravastatin | 5 | 6.20 (−5.30, 17.7) ns | 6.36 (2.14, 10.6) | 6.34 (−0.16, 12.8) ns
Pravastatin high dose | 2 | 10.3 (−4.28, 25.0) ns | 9.6 (9.31, 9.09) | 8.73 (−1.49, 19.0) ns
Pravastatin low dose | 3 | 2.46 (−4.40, 9.36) ns | 4.00 (1.31, 6.61) | 4.60 (−1.18, 10.4) ns
Simvastatin | 2 | 9.34 (3.28, 15.4) | 5.45 (1.94, 8.96) | 6.48 (2.04, 10.9)
Lovastatin | 8 | 11.27 (6.74, 15.8) | 11.1 (9.05, 13.1) | 8.74 (6.28, 11.2)
Atorvastatin | 3 | −2.32 (−5.00, 0.36) ns | 3.92 (−1.12, 8.96) ns | 9.10 (6.87, 11.3)^1^ (Pc < 0.01)
Caucasians | 17 | 11.1 (6.92, 15.3) | 8.10 (6.79, 9.41) | 7.92 (5.41, 10.4)
Asians | 3 | 3.58 (2.46, 4.70)^2^ | 3.88 (−0.06, 7.83) | 7.96 (4.37, 11.6) (Pc < 0.01)
Men | 5 | 11.5 (5.28, 17.6)^3^ | 6.73 (4.07, 9.38) | 10.1 (4.01, 16.3)
Women | 5 | 10.8 (6.62, 15.0)^4^ | 12.2 (3.94, 20.5) | 8.33 (3.07, 13.6)
Familial hyperlipidemia | 7 | 7.66 (3.25, 12.1) | 9.77 (6.78, 12.8) | 10.3 (5.93, 14.6)
Non-Familial hyperlipidemia | 14 | 10.4 (3.85, 16.9) | 6.26 (3.67, 8.84) | 5.23 (0.95, 9.51)
Short follow-up | 15 | 8.21 (5.67, 10.7) | 8.29 (6.05, 10.6) | 7.42 (5.40, 9.44)
Long follow-up | 5 | 6.86 (−7.21, 20.9) ns | 5.06 (0.30, 9.82) | 6.40 (−0.86, 13.7) ns
Diabetes | 2 | −1.89 (−3.96, 0.18)^5^ ns (Pc < 0.01) | 2.00 (0.86, 3.15)^6^ | 8.57 (4.46, 12.7)^7^
No diabetes | 19 | 10.4 (6.44, 14.30) | 8.12 (6.87, 9.36) | 7.63 (5.23, 10.0)

1 P_Q_ = 0.70, I^2^= 0;

2 P_Q_ = 0.43, I^2^= 0;

3 P_Q_ = 0.30, I^2^= 18%;

4 P_Q_ = 0.56, I^2^= 0%;

5 P_Q_ = 0.72;

6 P_Q_ = 0.98;

7 P_Q_ = 0.62;

ns, non-significant

Figure 3.7 Individual and pooled estimates of percent changes in high-density lipoprotein from baseline in e2-carriers with treated with statins

(Data are plotted in ascending order of baseline HDL levels. The analysis used a random-effects model)

Figure 3.8 Individual and pooled estimates of percent reduction in high-density lipoprotein from baseline in e3 homozygotes with statins

(Data are plotted in ascending order of baseline HDL levels. The analysis used a random-effects model)

Figure 3.9 Individual and pooled estimates of the reduction in high-density lipoprotein among e4 carriers treated with statins

(Data are plotted in ascending order of baseline HDL levels. The analysis used a random-effects model)

### Key Question #2 What demographic or clinical variables mediate the association between pharmacogenomic test results and biochemical or clinical outcomes among patients taking statin therapy?

For comparisons among genotypic groups, the response to statin therapy for HDL levels was significantly associated with atorvastatin, Asian descent, and diabetes (Table 3.4). Analyses by type of statin were contradictory. The studies of lovastatin had results similar to the main analysis. In studies of simvastatin, e2 carriers responded better, followed by e4 carriers. Increases in HDL were significant for simvastatin and lovastatin. For atorvastatin, only e4 carriers had a significant increase in HDL. For both low-and high-doses of pravastatin, only e3 homozygotes had a significant increase.

In Caucasians, the response to statin therapy was consistent with the main analysis. In Asians, the presence of the e4 allele was associated with a significantly greater response. In men, e2 and e4 carriers had a better response, whereas women who were e3 homozygotes had the greatest increase. In studies of patients without familial hyperlipidemia and diabetes, results were similar to those of the main analysis. In patients with familial hyperlipidemia, e4 carriers had the highest response, followed by the e3 homozygotes. In patients with diabetes, HDL levels increased significantly (Pc < 0.01) in e4 carriers but decreased in e2 carriers. In studies with long follow-ups, the results were significant only for the e3 homozygotes.

### Key Question #1 Among patients taking statin therapy, is there any association between carrying the Apo E genotype and biochemical variables, such as total, LDL, or HDL cholesterol or triglyceride levels?

#### Triglycerides

Twenty-eight studies investigated the association between the Apo E genotype and decreases in TG levels with statin therapy. 53,83–87,91–93,95,96,99–101,107,108,110,112–116,118,119,122,124,125 In 24 of the 28 studies, treatment with statins was not associated with significant changes in TG levels in any setting.53,83–87,91,92,95,96,99–101,107,108,110,112–116,119,122,124 Three studies reported that e4 carriers had significantly lower TG levels with therapy than did those with other genotypes; 93,113,118 Two other studies reported that e2 carriers had a better response to statins. 109,125 Quantitative data from 20 studies were included in the meta-analysis.83,85,87,91,95,100,101,107,110,113–115,118,122,124,125

The meta-analysis for e2 carriers, e3e3 homozygotes, and e4 carriers showed substantial heterogeneity between studies (P < 0.10, I^2^ ≥ 50%) as well as a significant percentage reduction in the pooled mean TG levels: Δμ = −17.0% (−22.5% to −11.5%), Δμ = −12.3% (−16.4% to −8.22%), and Δμ = −13.6% (−16.2% to −10.9%), respectively (Table 3.5; Figures 3.10–3.12). Overall, the genotypes did not differ significantly (Pc ≥ 0.05).

Table 3.5 Results of the meta-analysis and subgroup analyses for associations between the Apo E genotype and triglyceride levels in patients treated with statins

Variable | Number of studies | Mean change in TG (%) from baseline for e2 carriers (95% CI) | Mean change in TG (%) from baseline for e3e3 homozygotes (95% CI) | Mean change in TG (%) from baseline for e4 carriers (95% CI)
All | 20 | −15.6 (−19.5, −11.7) | −12.1 (−15.4, −8.77) | −13.3 (−15.9, −10.7)
Pravastatin | 6 | −14.0 (−21.6, −6.42) | −6.48 (−9.53, −3.43) | −9.2 (−15.2, −3.05)
Pravastatin high dose | 3 | −13.4 (−26.9, 0.18) ns | −9.89 (−19.0, −0.78) | −11.1 (−24.3, 2.13) ns
Pravastatin low dose | 3 | −15.6 (−26.2, −5.04) | −5.67 (−8.59, −2.75) (Pc = 0.04) | −7.54 (−14.6, −0.42)
Simvastatin | 3 | −25.8 (−34.5, −17.1) | −13.5 (−22.6, −4.37) | −11.9 (−25.3, 1.44) ns
Lovastatin | 5 | −15.1 (−22.9, −7.30) | −17.4 (−21.0, −13.9) | −17.5 (−21.2, −13.2)
Atorvastatin | 3 | −22.9 (−29.1, −16.7) | −15.3 (−18.4, −12.2) | −21.6 (−25.7, −17.5)
Caucasians | 15 | −17.5 (−22.1, −12.9) | −12.8 (−17.8, −7.81) | −15.7 (−20.5, −10.8)
Asians | 4 | −11.6 (−25.9, 2.72) ns | −10.4 (−16.3, −4.16) | −6.84 (−12.6, −1.04)
Men | 3 | −26.7 (−36.2, −17.1) | −11.5 (−16.6, −6.48) (Pc < 0.01) | −12.0 (−27.1, 3.11) ns
Women | 3 | −26.5 (−34.5, −18.4) pQ = 0.13 | −13.7 (−26.1, −1.27) | −18.6 (−31.1, −6.07)
Familial hyperlipidemia | 6 | −16.4 (−22.4, −10.4) | −17.9 (−21.2, 14.6) | −19.6 (−24.0, −15.3)
Non- Familial hyperlipidemia | 15 | −14.3 (−18.9, −9.69) | −10.5 (−14.1, −6.79) | −10.5 (−13.2, −7.92)
Short follow-up | 14 | −15.1 (−20.2, −10.0) | −14.2 (−17.9, −10.6) | −15.3 (−19.7, −10.9)
Long follow-up | 5 | −6.79 (−7.53, −6.05) | −6.79 (−11.4, −2.17) | −9.27 (−17.2, −1.32)
Diabetes | 3 | −12.6 (−26.5, 1.35) ns | −11.2 (−16.9, −5.56) | −13.1 (−20.9, −5.37)
No diabetes | 17 | −16.9 (−21.1, −12.6) | −12.5 (−17.2, −7.75) | −13.8 (−16.7, −11.0)

Figure 3.10 Individual and pooled estimates of the reduction in triglycerides among e2-carriers treated with statins

(Data are plotted in ascending order of baseline triglyceride levels. The analysis used a random-effects model)

Figure 3.11 Individual and pooled estimates of the reduction in triglycerides among e3 homozygotes treated with statins

(Data are plotted in ascending order of baseline triglyceride levels. The analysis used a random-effects model)

Figure 3.12 Individual and pooled estimates of the reduction in triglycerides among e4 carriers treated with statins

(Data are plotted in ascending order of baseline triglyceride levels. The analysis used a random-effects model)

### Key Question #2 What demographic or clinical variables mediate the association between pharmacogenomic test results and biochemical or clinical outcomes among patients taking statin therapy?

Pooled differences in TG levels by genotype were significant only for men. Results for the type of statin were contradictory. The results for atorvastatin were similar to those of the main analysis. In studies with pravastatin and simvastatin, e2 carriers responded better, followed by e4 carriers. In studies with lovastatin, e4 carriers had a greater mean decrease, followed by e3e3 homozygotes. Caucasians, women, and patients without diabetes had results similar to those of the main analysis. In Asians, the e2 carriers and the e3 homozygotes had a greater response than did e4 carriers. In patients with familial hyperlipidemia, the e4 allele was associated with a better response, followed by the e3 homozygotes and e2 carriers.

### Key Question #1 Among patients taking statin therapy, is there any association between carrying the Apo E genotype and other lipid or biochemical variables?

#### Apolipoprotein A1

Seven studies investigated the effect of statins on Apo A1 levels in association with the Apo E genotype.53,84,100,101,108,116,122 Treatment with statins was not associated with significant changes in Apo A1 levels in any setting. No study found significant associations between the Apo E genotype and changes in Apo A1 levels following treatment with statins.

Five studies were included in the meta-analysis.53,100,101,116,122 The meta-analysis showed substantial heterogeneity between studies (P < 0.10, I^2^ ≥ 50%). The pooled increase in Apo A1 from baseline (95% CI) was significant for e2 carriers and e3e3 homozygotes, with Δμ = +2.76% (0.81% to 4.71%) and Δμ = +2.41% (1.97% to 2.86%), respectively (Table 3.6). Overall, the genotypes did not differ significantly (Pc ≥ 0.05).

### Key Question #2 What demographic or clinical variables mediate the association between pharmacogenomic test results and biochemical or clinical outcomes among patients taking statin therapy?

Changes in Apo A1 levels among Caucasian and Asian e2 carriers treated with pravastatin did not differ significantly, contradicting with the main analysis. Among patients treated with lovastatin, e3e3 homozygotes differed significantly from both e2 and e4 carriers (Table 3.6).

Table 3.6 Results of the meta-analysis and subgroup analyses for associations between the Apo E genotype and Apo A1 levels in patients treated with statins

Variable | Number of studies | Mean change in Apo A1 (%) from baseline for e2 carriers (95% CI) | Mean change in Apo A1 (%) from baseline for e3 homozygotes (95% CI) | Mean change in percentage Apo A1 for e4 carriers (95% CI)
All | 5 | 2.76 (0.81, 4.71) | 2.41 (1.97, 2.86) | 1.99 (−0.94, 4.92)^1^ ns
PRAVA low dose | 2 | 4.45 (−1.54, 10.4) ns | 2.17 (1.64, 2.70) | 2.22 (0.46, 3.99)
Lovastatin | 2 | 7.61 (0.01, 15.2) | 3.00 (2.22, 3.78) (Pc < 0.01) | 0.22 (−4.07, 4.50) ns (Pc < 0.01)
Caucasians | 3 | 2.66 (−0.63, 5.96) ns | 2.87 (2.13, 3.60) | 2.41 (−2.89, 7.70) ns
E. Asians | 2 | 4.45 (−1.54, 10.4) ns | 2.17 (1.64, 2.70) | 2.22 (0.46, 3.99)

1 P_Q_ < 0.01, I^2^=85%;

ns = non-significant

#### Apolipoprotein B

Ten studies investigated the effect of statins in lowering Apo B levels among patients with the Apo E genotype.53,84,86,89,100,103,108,116,122,124 Six studies found no significant effect,53,84,86,89,103,116 and one study reported that e4 carriers responded less well.108 Another found that e2 carriers responded less well,122 whereas two studies found that e2 carriers responded better than did other groups.100,124 Five studies were included in the meta-analysis.53,94,100,116,122

The meta-analysis of e2-carriers, e3e3 homozygotes, and e4-carriers on the effect of statin therapy on Apo B levels showed substantial heterogeneity between studies (P < 0.10, I^2^ ≥ 50%). The mean reduction in Apo B (95% CI) was significant for each genotype: Δμ = −28.9% (−39.9% to 17.8%), Δμ = −25.5% (−31.2%, to−19.9%) and Δμ = −24.8% (−31.3% to −18.3%), respectively (Table 3.7). Patients with the e2 allele had the greatest reductions in Apo B levels, followed by those with the e3e3 and the e4 alleles (Table 3.7). The results of subgroup analyses (Table 3.7) were consistent with those of the main analysis.

Table 3.7 Results of the meta-analysis and subgroup analyses for associations between the Apo E genotype and Apo B levels in patients treated with statins

Variable | Number of studies | Mean change in Apo B (%) from baseline for e2 carriers (95% CI) | Mean change in Apo B (%) from baseline for e3e3 homozygotes (95% CI) | Mean change in Apo B (%) from baseline for e4 carriers (95% CI)
All | 5 | −28.9 (−39.9, −17.8) (Pc<0.05) | −25.5 (−31.2, −19.9) | −24.8 (−31.3, −18.3) (Pc<0.05)
Pravastatin low dose | 2 | −24.6 (−54.6, 5.43) ns | −21.7 (−32.1, −11.3) | −16.7 (−18.3, −15.2)
Caucasians | 2 | −31.4 (−45.4, −17.3) | −28.0 (−33.3, −22.6) | −27.9 (−31.0, −24.9)^1^
Asians | 3 | −27.18 (−46.7, −7.64) | −24.0 (−32.7, −15.4) | −22.5 (−33.8, −11.2)

1 P_Q_=0.98, I^2^=0;

ns=non-significant

#### Serum Apolipoprotein E levels

Four studies investigated the ability of statins to lower serum Apo E in patients in association with the Apo E genotype.53,86,100,122 Three studies were included in the meta-analysis.53,100,122 Studies reported no significant association between the Apo E genotype and an Apo-E lowering effect of statins.

The meta-analysis for e2-carriers, e3e3 homozygotes, and e4-carriers showed that there was substantial heterogeneity between studies (P < 0.10, I^2^ ≥ 50%) and that the mean pooled change in Apo E from baseline (95% CI) was significant for e3e3 homozygotes and e4 carriers: Δμ = −34.4% (−68.7% to −0.12%) and Δμ = -35.2% (−57.9% to −12.4%), respectively (Table 3.8). Subgroup analyses indicated that Caucasian ethnicity might contribute to the heterogeneity of results.

Table 3.8 Results of the meta-analysis and subgroup analyses for associations between the Apo E genotype and Apolipoprotein E levels in patients treated with statins

Variable | Number of studies | Mean change in serum Apo E (%) from baseline for e2 carriers | Mean change in serum Apo E (%) from baseline for e3 homozygotes | Mean change in serum Apo E (%) from baseline for e4 carriers
All | 3 | −45.0 (−5.9, 5.92) ns | −34.4 (−68.7, −0.12) | −35.2 (−57.9, −12.4)
Pravastatin low dose | 2 | −22.8 (−32.3, −13.8)^1^ | −19.1 (−26.1, −12.0)^2^ | −21.3 (−26.0, −16.7)^3^
Caucasians | 1 | −88.8 (−92.9, −83.1) | −68.6 (−74.5, 62.7) | −64.6 (−75.6, −53.6) (Pc < 0.01)
Asians | 2 | −22.8 (−32.3, −13.8)^1^ | −19.1 (−26.1, −12.0)^2^ | −21.3 (−26.0, −16.7)^3^

1 P_Q_ = 0.91;

2 P_Q_ = 0.16;

3 P_Q_ = 0.73;

ns = not significant

#### Miscellaneous biochemical variables

A few studies evaluated other lipid and biochemical variables: Apolipoprotein CII (Apo CII), C-reactive protein (CRP), cholesteryl ester transfer protein (CETP), plasma phospholipid transfer protein (PLTP), pseudocholinesterase (Pche), lipoprotein (a) (Lp (a)), and non-HDL cholesterol.

Statin therapy did not significantly change the levels of Apo CII, and this result was independent of the Apo E genotype.101,117 One cross-sectional study of statin-treated individuals participating in the AGES-Reykjavik Study reported that one or two e4 allele carriers had significantly lower CRP levels than did non-carriers and that this effect was dose-dependent on the number of alleles.94 E4 carriers had higher TC and lower TG levels irrespective of being treated with statins or not, suggesting that the e4 allele lowers CRP levels independently and perhaps by a different mechanism.

Lovastatin significantly reduced CETP activity independently of the Apo E genotype.101 Atorvastatin decreased PLTP independently of the Apo E-genotype in one study.104 Pravastatin did not significantly influence Pche activity (an enzyme involved in TG metabolism) in any of the three Apo E genotype groups.115 One study found that Apo E genotype did not affect the response to statin treatment for Lp (a).84 Another found that statins significantly decreased non-HDL levels and that this effect was not influenced by the Apo E genotype. 120

#### Adverse reactions response - Discontinuation of statins

Maitland-van der Zee reported that adherence was lower and the risk of discontinuation was 2.3 times higher among e4 homozygotic patients,106 perhaps because of the lower therapeutic effectiveness of statins in these individuals.

### Key Question #3 How does the pharmacogenomic test result affect the decision to use statin therapy; that is, how often is therapy changed in response to the test result?

### Key Question #4 What benefits, harms, or adverse effects are experienced by patients on statins from treatment received after pharmacogenomic testing

No studies addressed these two key questions.

### Summary

In the studies of the Apo E genotype and statin treatment, the pooled change in total and LDL cholesterol from baseline was lower for all genotypic groups (e2 carriers, e3e3 homozygotes and e4 carriers) but without significant difference among groups. However, this analysis also found significant between-study heterogeneity. Although only a few studies were available for certain subgroups, they indicate that some factors may affect the investigated associations of Apo E with statin therapy: ethnicity, sex, familial hyperlipidemia, the type of statin used, and possibly the presence of diabetes. No studies evaluated the last two key questions on the impact of therapeutic choice and the benefits, harms, or adverse effects for patients from subsequent therapeutic management after pharmacogenetic testing for Apo E genotype.

### Discussion

For most of the studies investigating the Apo E genotype and statin treatment, the primary clinical outcomes included the reduction of TC and LDL. The meta-analysis for e2-carriers, e3e3 homozygotes, and e4-carriers showed large and significant heterogeneity among studies. Overall, the pooled change in TC and LDL from baseline was significant for all three genotypic groups. However, the significant heterogeneity of our results warrants a cautious interpretation. Among the factors that may impact the investigated association are ethnicity, familial hyperlipidemia, the type of statin used, sex, and possibly the presence of diabetes. However, the limited number of studies for certain subgroups (i.e. diabetes) is another limitation of our analysis.

For the pooled change in TC and LDL levels, comparisons across genotypes showed that e2 carriers had a better response to statin therapy, with a pooled estimate better than that of the e3 homozygotes and e4 carriers. In a large replication study with a sample size similar to the number of patients included in our meta-analysis, and with a more homogeneous population and intervention, with statin therapy, e2 carriers lowered their LDL by 3.5% (P = 0.001) over other groups.119 The direction and magnitude of this effect are the same as our findings and further support the association between the Apo E genotype and the lipid-lowering response to statin therapy. Although very small, this effect may be large enough to affect health on a population basis 88. Intervention studies with statins in the general population have shown that cardiovascular event rates can be reduced by 1%, for every 1% reduction in LDL.81