# Addendum

During the preparation of this report, domain experts identified 10 articles of observational designs that were published after the last search date. In this section we include four publications on nonoverlapping populations that are relevant to the key questions.70–73 Three studies evaluated the effects of variants of both CYP2C9 and VKORC1 on response to warfarin therapy.70–72 One study evaluated only VKORC1 variants.73 One study tested associations in populations of European descent,71 and three included populations of European and African American descent.70,72,73 All four studies were prospective.70–73 Schwarz found no association between CYP2C9 alleles and warfarin response (time to first INR within therapeutic range) in 297 patients starting on warfarin therapy.70 Less than 5% of patients had the CYP2C9 *2/*2, *2/*3, *3/*3 genotypes. Schwartz found associations between A/A haplotype of VKORC1 (A haplotype includes variants of rs9923231, rs2884737, rs9934438, rs8050894, and rs2359612) and decreased time to the first INR within the therapeutic range as well as time to the first INR greater than 4. Limdi and Wadelius found no association between VKORC1 alleles rs9934438 (in Limdi), and rs9923231 (in Wadelius) and risk of bleeding. 71,72 In each of these studies, homozygotes for the aforementioned VKORC1 variant alleles had increased odds for overanticoagulation (early INR values greater than 4) and increased risk for major bleeding among patients of European descent. In patients of African-American descent CYP2C9 or VKORC1 variants were not statistically significantly associated with response to warfarin therapy.72 Finally, Wang found an association between increased warfarin dose requirement and lower frequency of VKORC1 rs9923231 allele.73