# Section 4: Crosscutting methodological observations across the three topics

Here we summarize a range of methodological issues that we identified across the three topics. These issues are applicable to all three tests, which have quite different characteristics. In the first topic (CYP2D6 polymorphisms and tamoxifen response modification) we evaluate germline polymorphisms, i.e., heritable common variations. In the other two cases we examine somatic mutations, i.e., genetic variations that are not heritable, and may evolve during the course of the disease. In the KRAS case mutations were relatively frequent, but the T315I mutation in BCR-ABL1 is relatively rare. We comment only on methodological issues that we came across in the three topics; broader consideration of this literature is outside the scope of this work.

Study design issues
- By definition, a pharmacogenetic interaction implies that the genetic factor has differential effects on outcomes in treated versus untreated patients. One can test for interactions between treatment and genetic variants, by analyzing both treated and untreated patients. However, interaction tests were not reported in studies in the CYP2D6 and BCR-ABL1 topics (they were reported by some studies in the KRAS topic). Most studies analyze only treated patients, effectively assuming that effects in untreated patients are zero.^a^ As we noted in Section 1.4, testing for gene by treatment interactions (when possible) is more than a formality; it presents the opportunity to triangulate results on the main effects, i.e., to perform a “reality check” on whether all analyses point to the same direction.
  a Otherwise one cannot distinguishif the genetic factor is prognostic (identifies heterogeneity in disease course irrespective of treatment) or predictive (identifies heterogeneity in treatment response)
- It may not be necessary to design new studies to address pharmacogenetic associations. It is possible to “repurpose” already completed RCTs in which the drugs of interest are tested against a suitable comparator. One would perform genetic analyses in archival tissue from RCT enrollees, and associate them with the prospectively recorded clinical outcomes.
- Included studies often had small sample sizes. It is therefore likely that they will have low statistical power to detect modest or small effects (odds ratios less than 1.5 or 1.2, respectively). There are no empirical data on the typical effect sizes for pharmacogenetic associations, for germline or somatic variations, common or rare. The vast majority of genetic associations of complex diseases have association odds ratios less than 1.5,(157;158) and many independently replicated ones have even smaller effects (OR<1.10). If this is also true for most pharmacogenetic associations, it is likely that large sample sizes are necessary to attain sufficient statistical power.
- We found no evidence on whether patient or disease relevant factors affect the strength of the examined association between genetic factors and treatment effect modification. Such evidence would be obtained by examining interaction effects between the factors of interest and the genetic factors. However, no study performed interaction analyses. Several studies performed simple adjustments for patient level factors. This is not only not informative, but also questionable from a methodological standpoint, because of mendelian randomization (see below).

Heterogeneity in the classification of genetic factors
- We documented extensive heterogeneity in the definitions of CYP2D6-derived metabolizer categories across the included studies (Figure 3), stemming from the large number of genotypes that can be studied. This is expected to be a common challenge, especially for multiallelic systems where many possible genotypes can be formed, and even more genetic contrasts (comparisons between genotypic groups) can be analyzed. Determining the clinically meaningful genetic comparisons in a multiallelic system is challenging, and offers opportunities for data dredging. It is not easy to select genetic contrasts solely based on biological rationale. After all, biological plausibility can be invoked retroactively and with relative ease(40) in support of even non-intuitive genotype comparisons.
- These and other challenges limit the usefulness of meta-analysis of aggregate level data. As was discussed in sections 1.4 and 3.4, meta-analyses of individual patient data are better suited to explore the complex relationships between genetic factors, treatments and outcomes.

Outcomes
- Most studies assessed surrogate short term outcomes of treatment failure, as defined by imaging or laboratory measurements. Data on the clinical outcomes of overall or progression-free survival are sparse.
- Further, no study reported details on changes in treatment decisions before and after testing. This absence of evidence may have different interpretation in the three settings. For example, KRAS testing is already used to guide treatment in several clinical settings, and thus affects treatment choice in these settings. This may not be the case in CYP2D6 testing, which is not in clinical use. The absence of the information requested by Key Question 3 is essentially an issue of reporting.
- Finally, there was no direct evidence on benefits and harms associated with testing and its downstream effects beyond the evidence that was described in Key Question 1. This is hardly surprising: Like all tests, genetic testing exerts most of its effects in an indirect way: test results affect subsequent patient management decisions, which in turn impact on patient-relevant outcomes.(41) Harms are often reported inadequately in RCTs(42) and nonrandomized studies of interventions,(43) and reporting may be even worse for studies of medical tests.

Statistical analyses
- Finally, many studies followed poor analytic practices, by performing statistical adjustments for factors that cannot confound the relationship between the genetic factor and the outcome. This is particularly true for germline genetic variations, such as the ones in CYP2D6, because mendelian randomization (the natural randomization of genotypes during mitosis) protects the relationship between polymorphisms and outcomes from confounding. Table 6 in section 1.4 discussed some examples of factors or design characteristics that can confound or bias relationships in classical epidemiology, but not in genetic epidemiology. We remind the reader that associations of germline genetic variations are not immune to bias;(48) rather, a different set of considerations is applicable to such studies. Multiplicity of comparisons, data dredging, population stratification, and misclassifications of outcomes and genotypes and various biases (including publication and reporting biases) are the most common threats to the validity of associations between genetic factors and treatment effect modification.
- Theoretically, in repurposed RCTs, retrospective associations of both germline genetic variations and somatic mutations with outcomes should be unconfounded. A repurposed RCT would resemble a factorial randomized trial: the randomization process ensures that the treatment is allocated randomly. Mendelian randomization ensures that the germline genetic variations are allocated randomly across treatment arms. The randomization process itself ensures that somatic variations are randomly allocated.
- Adjustments for multiple comparisons were not documented in the included studies. This is a major issue in genetic epidemiology, because of the large number of possible hypotheses that can be examined.

Other issues
- Multiple studies on each topic frequently originated from a limited number of specialized centers, posing problems in identifying nonoverlapping populations, and potentially limiting the generalizability of the findings.