# Section 3: Variations in BCR-ABL and response to imatinib, dasatinib and nilotinib in chronic myeloid leukemia

## 3.1 Background

Chronic myeloid or myelogenous leukemia (CML) is a relatively uncommon hematological malignancy with approximately 5,000 new cases diagnosed annually.(115) CML was the first malignant disorder where a single chromosomal aberration was demonstrated to be fundamental to the etiology of the disease.(116) The Philadelphia chromosome, designated t(9;22)(q34;q11), a reciprocal translocation between chromosome 9 and 22, produces the BCR-ABL1 fusion protein,^a^ a constitutively active tyrosine kinase that activates several signal transduction pathways. This ultimately causes abnormal bone marrow proliferation and the clinical manifestations of CML.

a Formally designated Bcr-Abl

The identification of the BCR-ABL1 fusion gene has also advanced the development of several laboratory tests, especially for molecular monitoring of residual disease after treatment. Tests for monitoring response include conventional G-banded karyotypic examination, fluorescence in situ hybridization (FISH), and quantitative reverse transcriptase polymerase chain reaction (RT-PCR).(117) For example, qualitative RT-PCR is routinely used for molecular monitoring of BCR-ABL1 transcript levels to assess patient response to therapy. Another routinely used test for patient monitoring patient response is cytogenetic monitoring with conventional karyotypic examination.

The advent of imatinib a tyrosine kinase inhibitor (TKI) drug that specifically blocks the activity of the BCR-ABL1 tyrosine kinase, has dramatically modified the clinical management of CML in this decade.(118) Imatinib as first-line therapy is now considered the standard of choice for most untreated patients with CML in chronic phase.(118) According to the 6-year followup results of a randomized trial^b^ comparing interferon with imatinib in previously untreated chronic phase CML patients, about 80 percent of imatinib-treated patients enjoy long-term survival with no evidence of overt disease progression.(119) Some patients do not benefit from imatinib treatment. These include patients with suboptimal or no response to imatinib, patients who eventually develop resistance to first line therapy with imatinib, or those with CML in advanced disease (i.e., accelerated or blastic phase). Several therapeutic options are available for these patients, including high-dose imatinib,^c^ the newer generation TKIs dasatinib and nilotinib,^d^ and allogeneic stem-cell transplantation.(118)

b This is the IRIS trials, the International Randomized Study of Interferon versus STI571 (imatinib). This study included CML patients in the chronic phase who were previously untreated.

c 600 to 800 mg/d – versus 400 mg/d of the standard dose.

d Dasatinib and nilotinib are FDA approved second line treatments.

The emergence of point mutations in the kinase domain of the BCR-ABL1 gene is generally considered one of the most common and critical mechanisms of clinical resistance to imatinib treatment.^e^(120) Kinase domain mutations in BCR-ABL1 was first identified by direct sequencing in 2001, in 11 patients who failed imatinib therapy.(121) Since then, several studies have examined these mutations in patients with clinical resistance to imatinib using several technologies.(122) To date, over 70 different mutation positions involving 57 different amino acids have been reported.(122) A particular mutation, T315I, is now considered to be a marker of poor response to all FDA-approved TKIs. The updated clinical recommendations by the European Leukemia Net (ELN) advocates performing mutation analysis in patients with suboptimal response or failure to any TKIs. ELN advocates that patients with the T315I mutation should consider allogeneic stem cell transplantation.(118)

e Other proposed mechanisms of clinical resistance to imatinib include BCR-ABL1 gene-independent mechanisms such as pharmacokinetic factors, aberrant intracellular uptake of imatinib or clonal evolution, or BCR-ABL-related mechanisms like overexpression.(120)

In this Technology Assessment we perform a systematic review of the published evidence on the ability of mutation testing in the BCR-ABL1 gene to predict patient response to therapy with TKI inhibitors. We consider separately first, second and third line treatments of CML.

## 3.2 Methods

The reader is referred to the Generic Methods Section for a description of methods common to all three topics examined in this review. Herein we describe the topic-specific Key Questions, as well as additional topic-specific methods.

### Key Questions

5) Does BCR-ABL1 mutation testing predict response to TKI therapy?
6) What patient- and disease-relevant factors affect the test results, their interpretation or their predictive response to therapy?
7) How does the gene testing impact the therapeutic choice?
8) What are the benefits and harms or adverse effects for patients when managed with gene testing?

The reader is referred to the Generic Methods section in the beginning of this Technology Assessment for a description of the Key Questions.

### Literature search

We searched Ovid MEDLINE from inception to August week 4, 2009 using combinations of the terms “chronic myeloid leukemia”, “imatinib”, “dasatinib”, “nilotinib” and their synonyms. The exact search strategy is listed in Appendix A. We also perused the reference list of eligible studies and of relevant review articles.

### Eligibility criteria

In order to be eligible for this review, studies needed to meet the generic eligibility criteria. In addition, eligible studies included patients with BCR-ABL1 positive CML, regardless of disease stage (chronic, accelerated, or blastic phase) or treatment context (first line, second line, or subsequent lines), who received imatinib, dasatinib, or nilotinib with or without concurrent other chemotherapy. Outcomes of interest were overall or CML specific mortality, CML progression (as defined by each study), or TKI treatment failure (lack of hematologic, cytogenetic, or molecular response, as defined by each study).

The main focus is on studies that performed mutation testing in samples obtained before the initiation of treatment (Figure 8). After discussions with AHRQ and TOO we decided to also abstract studies that performed mutation testing during treatment, to monitor patients for treatment failure (monitoring studies Figure 9). These are summarized separately at the end of this section.

### Data extraction

The reader is referred to the Generic Methods section in the beginning of this Technology Assessment for a description of the Data extraction for common items across the three topics.

#### Technical specifications of tests to detect BCR-ABL1 mutations, and mutation frequency

We extracted information on tissue source (e.g., peripheral blood or tissue source), mutation detection method, tested gene region, assay detection sensitivity, identified mutations, and BCR-ABL1 transcripts level (or trend) collected most recent to mutation testing.(122)

Laboratory guidelines have proposed an operational classification of mutations in the BCR-ABL1 gene.(122;123) We recorded the frequency of each reported mutation in each study, and present a graphical summary of these frequencies

#### Outcomes of interest

As described in the Generic Methods section outcomes of interest were overall survival and cancer specific survival; progression-free or event-free survival (as defined by each study); and treatment failure. Typically, treatment failure is defined as absence of hematologic, cytogenetic, or molecular response to treatment, according to various criteria (European Leukemia Net, ELN,(118;124) criteria or other).

### Definition of treatment categories

We grouped therapies into the following operational categories, irrespective of dose or dosing schedule unless noted otherwise:

1. Standard dose imatinib monotherapy (<=600 mg per day)
2. High dose imatinib monotherapy (>600 mg per day)
3. Imatinib-based combinations, which including non-TKI therapies added to imatinib
4. Dasatinib monotherapy
5. Nilotinib monotherapy
6. Miscellaneous. This category refers to (study) results of multiple TKI agents that do not provide separate data for each TKI^a^
  a Not about a concurrent administration of two (or more) different TKIs.

### Lines of TKI therapy

For the purpose of this report we used the following operational classification of studies:

1. First line TKI therapy studies: Studies in patients who have not received prior TKI treatment. Typically, these are studies of standard dose imatinib monotherapy.
2. Second line TKI therapy studies: Studies in patients in whom prior treatment with standard dose imatinib was not successful. Typically, these are studies of high dose imatinib monotherapy, imatinib-based combinations, dasatinib or nilotinib.
3. Third line TKI therapy studies: Studies in patients in whom first and second line therapies were not successful. These would generally be studies classified in the “miscellaneous” category in our operational classification of treatments.

### Differential timing of mutation testing by line of TKI therapy

The following schematics help clarify the temporal relationship of BCR-ABL1 mutation testing and treatment for first, second, and third line TKI therapy studies.

In first line TKI therapy studies mutation testing is performed in samples obtained before the initiation of first line therapy, as shown in Figure 8. The corresponding timing between testing and treatment is required for second and thirds line TKI therapy studies.

We also abstracted studies that used BCR-ABL1 mutation testing during therapy, presumably to monitor patients for treatment failure (Figure 9). These studies are summarized separately.

As described in the eligibility criteria, studies that perform mutation testing only among patients with treatment failure and do not associate this information with response to subsequent therapy are excluded (Figure 10).

Figure 8 BCR-ABL1 and tyrosine kinase inhibitors for CML: timing of mutation testing and TKI therapy in studies predicting treatment failure

In studies predicting response to treatment (the main focus of this Section), mutation testing must be performed prior to initiation of first, second or third line TKI therapy (not shown for third line therapy studies).

figure 8. "BCR-ABL1 and tyrosine kinase inhibitors for CML: timing of mutation testing and TKI therapy in studies predicting treatment failure. (page 83) Figure 8 shows timing of BCR-ABL1 mutation testing in studies predicting response to first or second line tyrosine kinase inhibitor treatment. In studies predicting response to treatment (the main focus of this Section), mutation testing must be performed prior to initiation of first, second or third line TKI therapy (not shown for third line therapy studies). For patients in first line imatinib therapy, testing must be performed prior to initiation of therapy. For patients in second line therapy, testing must be performed for no responders (or failures) to first line imatinib therapy, prior to initiation of the second line therapy, which includes high dose imatinib, imatinib and other agents, dasatinib, or nilotinib."

Figure 9 BCR-ABL1 and tyrosine kinase inhibitors for CML: timing of mutation testing in studies that monitor patients for treatment failure

In studies that monitor patient response, mutation testing is performed during therapy. Possible reasons are to identify treatment must be performed prior to initiation of first, second or third line TKI therapy (not shown for third line therapy studies).

Figure 9. BCR-ABL1 and tyrosine kinase inhibitors for CML: timing of mutation testing in studies that monitor patients for treatment failure. (page 83) Figure 9 shows timing of BCR-ABL1 mutation testing in studies monitoring mutation status to predict treatment response in first line tyrosine kinase inhibitor treatment. In these studies, mutation testing is performed at single or multiple time points during therapy (not shown for second or third line therapy studies).

Figure 10 BCR-ABL1 and tyrosine kinase inhibitors for CML: timing of mutation testing relative to treatment initiation and outcome assessment in excluded studies

Studies that perform mutation testing only in non responders and do not associate this information with response to subsequent therapy are excluded from this report.

Figure 10. BCR-ABL1 and tyrosine kinase inhibitors for CML: timing of mutation testing relative to treatment initiation and outcome assessment in excluded studies. (page 84) Figure 10 shows the relative timing of mutation test in excluded studies. Studies that perform mutation testing only in non responders to a prior line tyrosine kinase therapy (first line imatinib therapy in this case) and do not associate this information with response to subsequent therapy (that is, second line therapy such as high dose imatinib, imatinib and other agents, dasatinib, or nilotinib) are excluded from this report. These studies do not have the data on clinical outcomes in the subsequent line therapy after the test.

### Synthesis

Please refer to the Generic Methods section for a description of study synthesis methodologies used in this Technology Assessment. We present results on the outcomes of overall or cancer specific survival, progression-free survival, and treatment failure separately for first, second, and third line TKI therapy studies, stratified by treatment category (as defined above).

We did not perform quantitative synthesis (meta-analysis). Data were very limited for survival or progression free survival. For the outcome of treatment failure there was extensive heterogeneity in the disease stage of included patients and in the definition of treatment failure across studies (section 3.3 Results). Instead, we perform qualitative syntheses through graphs and tables.

## 3.3 Results

Our electronic searches yielded 3388 studies, 162 of which were retrieved in full text (Figure 11). Finally, 31 publications were included. Appendices A and B list included and excluded papers, respectively.

Figure 11 BCR-ABL1 and tyrosine kinase inhibitors for CML: literature flow

Perusal of reference lists did not identify additional citations that were not found in the electronic searches.

Figure 11. BCR-ABL1 and tyrosine kinase inhibitors for CML: literature flow. (page 85) Figure 11 is a type of diagram that depicts the literature search, and literature scan. The electronic literature search (MEDLINE) yielded 3388 citations, of which 162 papers were retrieved in full text. 3, 20, 1, and 7 were considered for reviews of studies of first line, second line, and third line tyrosin kinase therapy, and monitoring, respectively, of which 31 were included. 131 were excluded for the following reasons: no BCR-ABL1 mutation testing performed (n=46), case series with fewer than 10 patients (n=17), treatment failures in a TKI therapy assessed for mutation without followup data after the test (n=17), only patients with mutations assessed (n=14), no clinical outcomes of interest reported (n=12), irrelevant (n=7), mutation testing performed but mutations not detected (n=5), review article with no primary data (n=4), patients do not take TKIs (n=3), mutation testing performed but no associations between mutation results and clinical outcomes reported (n=3), in vitro studies (n=2), or letter with no primary data (n=1). Perusal of references of the 31 selected papers did not yield any further eligible papers.

Figure 12 summarizes which publications appear to have common sets of patients. Most publications originated from the MD Anderson Comprehensive Cancer Center.

Figure 12 BCR-ABL1 and tyrosine kinase inhibitors for CML: potential overlaps in patient populations in first, second and third line therapy studies

Each ellipse is a citation included in the systematic review. Citations with at least partially overlapping patient populations are connected with a line. Refer to Tables 18, 21 and 28 to identify the citations of the depicted studies. Some second line therapy studies likely include some patients reported in the first line therapy studies. Similarly, Quintas-Cardama 2007 (third line therapy) likely includes patients who are also described in the first and second line therapy studies.

*Cortes 2007d likely includes patients from several studies of dasatinib (not depicted). Note that Kantarjian 2007b belongs to the “miscellaneous” (various) treatment category.

Figure 12. PBCR-ABL1 and tyrosine kinase inhibitors for CML: potential overlaps in patient populations in first, second and third line therapy studies. (page 86) Each ellipse is a citation included in the systematic review. Citations with at least partially overlapping patient populations are connected with a line. Refer to Tables CHAR_CML_1_LINE, CHAR_CML_2_LINE and CHAR_CML_3_LINE to identify the citations of the depicted studies. Some second line therapy studies likely include some patients reported in the first line therapy studies. Similarly, Quintas-Cardama 2007 (third line therapy) likely includes patients who are also described in the first and second line therapy studies. Cortes 2007d likely includes patients from several studies of dasatinib (not depicted). Note that Kantarjian 2007b belongs to the “miscellaneous” (various) treatment category. In the graph, many studies are linked with others, indicating that (at least partly) the studies population overlap.

### Key Question 1 Does BCR-ABL1 testing predict response to TKI therapy?

#### First line TKI therapy studies

##### Study characteristics

Three studies (from Germany, the UK, and the US) reported associations between BCR-ABL1 mutation testing and clinical outcomes in patients with CML (Table 20).(125–127) All three were single arm cohorts of patients receiving imatinib. Two are retrospective cohorts(125;127) and the third is a prospective single center phase I/II trial of imatinib treatment. All three have small sample sizes (10, 66, and 120).

As depicted in Figure 12 the three studies have nonoverlapping patient populations. Median ages ranged from 48 to 60 years, and approximately half of the participants were male. The two larger retrospective studies included patients in all disease stages (i.e., chronic, accelerated, or blastic phase), whereas the smaller phase I/II trial included mostly acute phase patients. Typically, baseline tumor load was not reported.

##### Mutation testing characteristics

Table 21 reports details on BRC-ABL mutation testing in the three studies. Studies considered various mutations as predisposing to adverse clinical outcomes. All studies tested for the T315I mutation. Figure 13 presents a graphical summary of the frequencies of detected mutations in all studies.

Table 20 BCR-ABL1 and tyrosine kinase inhibitors for CML: characteristics of included studies (first line therapy)

Author, year (Country) | -Sample size, n -Study design -Sampling | Selection criteria | Median age, y [range] (% Men) | Staging distribution, n (%) | Disease status | Median recent tumor load (range) | Prior therapy | -Treatment -Adherence | Median followup, mo [range]
Ernst, 2008 (Germany) (125) | -120 -Retrospective single center cohort study^a^ -Unclear | Patients with relapsed CML while on imatinib treatment (n=95) and patients with CML-CP with continuous CR for more than 2 years after imatinib monotherapy (n=25) were compared | Relapsed group^b^: 60 [20–80] (54) Responsive group: NR | Relapsed group^c^: CP 47 (50); AP 27 (28); BP 21 (22); Responsive group: CP 25 (100) | Median time since CML diagnosis 32 mo | NR | NR | -Imatinib 400–600 mg/d -NR | 13 [1–44]^d^
Willis, 2005 (USA)(127) | -66 -Retrospective analysis of a multi-center trial -Convenience sampling | NR | 57 [31–80] (42) | CP 20 (30); AP 27 (40); BC 19 (29) | NR | NR | No prior imatinib HU 51 (77); IFN 37 (56); Cytarabine 18 (27); TopoII 11 (17); 6TG 6 (9); BU 5 (8); L-PAM 3 (5); others 4 (6) | -Imatinib 400 mg/d (CP); Imatinib 600 mg/d (AP or BC) -NR | NR
Marin, 2005 (UK)(126)^e^ | -10 -Prospective single-center phase I/II trial -Unclear | Ph+ CML aged ≥18 y on imatinib 400 mg/d for ≥2 y Partially sensitive to imatinib but “suboptimal” response (≥minor CyR with a plateau in BCR-ABL1 transcripts) | 48 [41–70] (60) | AP 1 (10); NR 9 (90) | Complete CyR 8 (80); partial CyR 1 (10); minor CyR 1 (10) | 4.4% (0.03%–25%) | Imatinib 400 mg/d 10 (100); IFN 7 (70) | -Imatinib 400–600 mg/d + HHT 2×1.25 mg/m^2^/d for 1–3 d for every 4wk (adjusted according to toxicity) -Median 6.5 cycles (range, 4–8) | 6.5 [4–8]^f^

a Patients were participants in prospective multicenter trials.

b Median age [range] when starting imatinib.

c At imatinib resistance.

d Median time-to-hematologic relapse for patients who developed imatinib resistance. Responsive patients were in continuous response for at least 2 years.

e Addition of another agent to imatinib

f Duration of therapy

AP, accelerated phase; BP, blastic phase; BU, busulfan; CP, chronic phase; CR, complete remission; CYR, cytogenetic response; HHT, homoharringtonine; HU, hydroxyurea; IFN, interferon; L-PAM, melphalan; NR, not reported. Ph+, Philadelphia chromosome positive; TopoII, topoisomerase II inhibitor; 6TG, 6-thioguanine

Table 21 BCR-ABL1 and tyrosine kinase inhibitors for CML: detection and reporting of mutations conferring drug resistance

Study (first author, year) | Assessed patients, n (% of included patients) | Test Objective | Mutation detection method | Source (Tube) [process and time between collection and RNA extraction, h] | Detection sensitivity (%) | Mutation Frequency, n (%)
Study (first author, year) | Assessed patients, n (% of included patients) | Test Objective | Mutation detection method | Source (Tube) [process and time between collection and RNA extraction, h] | Detection sensitivity (%) | Mutation + | Mutation −
Ernst, 2008^a^ | 120 (100) | Response prediction | Nested PCR and DHPLC, DS | -Peripheral blood (commercial kits) -NR | -DHPLC: 0.1 for T315I/M351T; 0.5 for Y253F; 1 for E255K -Sequencing: 10 | Relapsed group: Any, 9 (9); T315I, 4 (4.2) Responsive group: Silent mutation, 1 (4); Normal polymorphism, 2 (2) | Relapsed group: 86 (91)
Willis, 2005 | 66 (100) 65 (98) [DS] | Predictive | ASO-PCR^b^ DS | -Bone marrow -NR | -ASO-PCR: 0.1 -DS: NR | Any, 14 (21) [ASO-PCR] Any, 2 (3) [DS] T315I, 8 (12) [ASO-PCR] T315I, 0 [DS]^c^ | 52 (79) [ASO-PCR] 63 (97) [DS]
Marin, 2005 | 10 (10) | Predictive | DS | -Peripheral blood or bone marrow -[NR] | -NR | Any, 2 (20) T315I, 0 (0) | 8 (80)

a Data were extracted only regarding mutations detectable prior to imatinib treatment.

b Only 8 mutants

c DS detected 1 case with F359V, which was not included in ASO-PCR

ASO-PCR = allele-specific oligonucleotide polymerase chain reaction; DHPLC = denaturing high-performance liquid chromatography; DS = direct sequencing; PCR = polymerase chain reaction; PS = pyrosequencing; SS = subcloning and sequencing

Figure 13 BCR-ABL1 and tyrosine kinase inhibitors for CML: frequencies of mutations

Mutation frequencies in the BCR-ABL1 gene are depicted using a colorcode. When a study reported multiple different mutated codons in patients, each different codon was considered independently. One study reported results by ASO-PCR and direct sequencing separately (Willis 2005a and Willis 2005b, respectively).(127). The mutation testing by ASO-PCR assessed only 8 “common” mutations (Q252H, Y253F, Y253H, E255K, E255V, T315I, M351T, F359V). In this case we considered the frequency of the mutations in unassessed codons to be 0. Because one study reported several variants in three codons as single group (*F359C/I/V, Y253F/H, and E255K/V), the estimated frequency was divided and assigned evenly to each variant.(128) One study selectively reported only 8 codons. In one study(129) some patients with specific mutations (L248V, G250E, Q252H/R, Y253H/F, E255K/V, T315I/D, F317L, and H396P/R) were excluded. Ernst 2008(125) was excluded because of case-control design (i.e., patients with treatment failure and those in continuous complete cytogenetic remission were separately identified).

Abbreviations: ASO-PCR, allele-specific oligonucleotide polymerase chain reaction; AP, accelerated phase; BP, blastic phase; Comb, imatinib-based combination; CP, chronic phase; HD, high-dose.

Figure 13. BCR-ABL1 and tyrosine kinase inhibitors for CML: frequencies of mutations. (page 90) When a study reported multiple different mutated codons in patients, each different codon was considered independently. One study reported results by ASO-PCR and direct sequencing separately (Willis 2005a and Willis 2005b, respectively). The mutation testing by ASO-PCR assessed only 8 “common” mutations (Q252H, Y253F, Y253H, E255K, E255V, T315I, M351T, F359V). In this case we considered the frequency of the mutations in unassessed codons to be 0. Because one study reported several variants in three codons as single group (*F359C/I/V, Y253F/H, and E255K/V), the estimated frequency was divided and assigned evenly to each variant.97 One study selectively reported only 8 codons. In one study98 some patients with specific mutations (L248V, G250E, Q252H/R, Y253H/F, E255K/V, T315I/D, F317L, and H396P/R) were excluded. Ernst 200894 was excluded because of case-control design (i.e., patients with treatment failure and those in continuous complete cytogenetic remission were separately identified). In general "all shades of gray" are present indicating that studies are relatively small and no mutation is clearly predominant.

###### Association of BCR-ABL1 mutation test results and mortality

Only Willis 2005 evaluated overall survival. The study found no statistically significant differences in the time-to-death among patients with versus without mutations (for all assessed mutations, hazard ratio not reported; log rank p=0.56).

###### Ability of BCR-ABL1 mutation testing to predict imatinib failure

Ernst 2008(125) and Willis 2005(127) reported relevant data. Ernst 2008 evaluated a composite of hematologic or cytogenetic response (no details on outcome definition). Willis 2005 evaluated complete or partial hematologic response (according to criteria described in reference(130)) or major cytogenetic response (as per the European Leukemia Net criteria, described in reference(118;124)). Table 22 summarizes calculated predictive accuracy results.

###### Association of BCR-ABL1 testing results and disease progression outcomes

Only Willis 2005 evaluated disease progression, defined as loss of partial or complete hematologic response, major cytogenetic response, initiation of alternate therapy or death. The study found no statistically significant differences in the time-to-event among patients with versus without mutations (for all assessed mutations, hazard ratio not reported; log rank p=0.90).

Table 22 BCR-ABL1 and tyrosine kinase inhibitors for CML: imatinib treatment failure(first line therapy)

Author, year | Outcome (followup) | BCR-ABL1 mutations | Mutation, no response | Mutation, response | No mutation, no response | No mutation, response | Sensitivity (95 %CI) | Specificity (95% CI) | LR positive | LR negative
Willis, 2005 | Hematologic response (ND) | All identified mutations | 5 | 9 | 8 | 41 | 0.38 (0.14, 0.68) | 0.82 (0.69, 0.91) | 2.14 | 0.75
Willis, 2005 | Hematologic response (ND) | T315I | 1 | 7 | 12 | 43 | 0.08 (0.00, 0.36) | 0.86 (0.73, 0.94) | 0.55 | 1.07
Willis, 2005 | Major cytogenetic response (ND) | All identified mutations | 11 | 3 | 31 | 17 | 0.26 (0.14, 0.42) | 0.85 (0.62, 0.97) | 1.75 | 0.87
Willis, 2005 | Major cytogenetic response (ND) | T315I | 6 | 2 | 36 | 18 | 0.14 (0.05, 0.29) | 0.90 (0.68, 0.99) | 1.43 | 0.95
Ernst, 2008 | Hematologic or cytogenetic response (1.1 y) | All identified mutations | 9 | 0 | 86 | 25 | 0.09 (0.09, 0.17) | 1.00 (0.86, 1.00) | 5.15^a^ | 0.92
Ernst, 2008 | Hematologic or cytogenetic response (1.1 y) | T315I | 4 | 0 | 91 | 20 | 0.04 (0.01, 0.11) | 1.00 (0.83, 1.00) | 1.97^b^ | 0.98

a A continuity correction of 0.5 was used in this calculation

b A continuity correction of 0.5 was used in this calculation

#### Second line TKI therapy studies

##### Study characteristics

In total 18 studies in 20 publications reported associations between BCR-ABL1 mutations and clinical outcomes in patients with CML (Table 23). (128;129;131–148) As evident from Figure 12, at least several studies have at least partially overlapping patient populations.

###### Patients

Overall, studies included patients who had already failed imatinib therapy. In most studies, the vast majority of patients had also received other therapies such as interferon (Table 23). Patients at different stages of CML (chronic, blastic or accelerated phase) were included across studies. Typically, prospective phase I (dose-finding) studies included any disease stages, whereas other prospective studies generally focused on only one particular disease stage (see “ Design”, below). The median age of included patients ranged from 50 to 62 years. Typically, baseline BCR-ABL1 transcript levels of patients were not reported. The median follow-up ranged 2 to 61 months. Most publications particularly in 2^nd^-line TKI treatments originated from MD Anderson Comprehensive Cancer Center.”

###### Treatments

Overall, second line TKI therapy studies treated patients with high dose imatinib monotherapy (n=2),(129;131) imatinib-based combinations (n=3),(132–134) dasatinib (n=10),(128;129;135–144) nilotinib (n=3),(145–147) or a combination of TKI drugs (“miscellaneous” category, n=1).(148) Doses and dosing schedules differed (Table 23). Typically, compliance or blood concentrations of TKIs were not reported.

###### Design

Across all treatment types, in 5 studies outcome assessment was retrospective.(128;131;144;146;148) Outcome assessment was prospective or unclear in the remaining 13 studies.(129;132–143;145;147) Three studies were based on RCTs that performed mutation testing either as part of their original protocol, or in the context of post hoc analyses.(129;135;138) The remaining studies evaluated patients who received specific protocols. None of the RCT-based studies assessed interactions of mutation status with treatment type for predicting outcomes. Instead, they performed statistical analyses only within patients who received specific treatments, much like the single arm studies.

All studies but one(148) assessed the predictive ability of the mutation testing as part of subgroup analyses. The sample size of the studies ranged from 18 to 670 (median, 114), and mutations were assessed in 30 to 100 percent (median, 92 percent) of total study participants. One RCT-based study compared high-dose imatinib with dasatinib,(129), and another two RCT-based studies performed comparisons different dosing schedules of dasatinib.(135;138) Eleven prospective single arm studies published in 13 publications evaluated the effects of one particular second-line TKI.(132–134;136;137;139;140;142;143;145–148) Three retrospective studies evaluated the effects of one particular TKI.(128;131;144) Of these, one(128) assessed a portion of the patients in three previous studies(129;135–137) and another(144) in the other previous study(142) (see Figure 12). Another retrospective study, in which at least several patients were likely to be included in some previous second line TKI therapy studies, assessed for chronological changes in mutation status as the main outcome.(148)

Table 23 BCR-ABL1 and tyrosine kinase inhibitors for CML: characteristics of included studies (second line therapy)

Author, year (Country) | -Sample size, n -Study design - Sampling | Selection criteria | Median age, y [range] (% Men) | Stage, n (%) | Disease status | Median Recent Tumor Load (range) | Prior therapy | -Treatment [n(%)] -Adherence | Median followup, mo [range]
High-dose Imatinib
Jabbour, 2009 (USA) | -84 -Prospective single-center cohort -Convenience sampling | CML in CP Failure to standard-dose imatinib therapy | 54 [18–79] (NR) | CP 84 (100) | Hematologic relapse 17 (20); Hematologic resistance 4 (5); cytogenetic relapse 33 (39); cytogenetic resistance 30 (36) | NR | Imatinib 400 mg/d 72 (86); Imatinib 300 mg/d 12 (14) | -Imatinib 800 mg/d 72 (86); Imatinib 600 mg/d 12 (14) -NR | 61 [7–89]
Imatinib-based Combination Chemotherapy
Cortes, 2007a (USA) | -26 -Prospective single-center phase I trial -Unclear | CML CP Imatinib failure (no or loss of CHR at 3 mo; no or loss of ≥ minimal CyR at 6 mo; no or loss of MCyR 12 mo) PS ≤2 (Zubrod) Cr and TBil <2 mg/dl WBC <30×10^9^/L Effective contraception for women | 62 [29–82] (46) | CP 26 (100) | NR | 23.84% (2.4%->100%) | Imatinib ≥400 mg/d 26 (100); IFN + Ara-C 10 (38); IFN + HHT 2 (8); IFN + imatinib 1 (4); IFN + GMCSF 1 (4); decitabine 3 (12); allogeneic SCT 3 (12) | -Imatinib 300 mg d1-21 + tipifarnib 300 mg d1-14 (adjusted according to toxicity) ; q21d -Median 8 cycles (range, 1–49) | 26^a^
Oki, 2006 (USA) | -28^b^ -Prospective phase II single-center clinical trial -Unclear | Histologically confirmed CML-AP or myeloid BP of chemotherapy for at least 2 weeks before study entry | 50 [26–75] (64) | AP 18 (68); BP 10 (32) | Imatinib resistance 25 (89) | NR | Imatinib only 10 (36); imatinib + other treatments 15 (54); no prior treatment 3 (11) IFN 10 (36); chemotherapy other than HU 4 (14); farnesyltrnsferase inhibitor 6 (21) homoharringtonine 4 (14) ; allogeneic SCT 3 (11) | -Imatinib 600 mg qd + Decitabine 15 mg/m^2^ qd IV over 1 hour for 10 days (Days 1–5 and 8–12), approximately every 6 weeks as indicated by follow-up counts and marrow studies -91 cycles were administered in total; 2.5 cycles per patient (range 1–12) | NR
Cortes, 2007b (USA) | -23 -Prospective single-center phase I trial -Unclear | Patients >=16 years with imatinib resistant CML (CP, AP, BP) | 55 [26–79] (NR) | CP 9 (39); AP 11 (48); BP 3 (13) | Imatinib resistance 23 (100) | NR | Imatinib 23 (100); IFN 16 (70); HU 7 (30); other [including homoharringtonine, decitabine, clofarabine] 7 (30) | -Imatinib 400 mg qd (600mg qd for advanced stages) + lonafarnib 100 mg bid -Dose escalation of lonafarnib was performed by 25 mg bid increments up to a maximum dose of 250 mg bid | CP: 8 [2–18] AP: 2 [1–4]
Dasatinib
Shah, 2008 (Multinational) | -670 -Multi-center open-label, phase III, 2×2 factorial study of different dasatinib administration schedules -Unclear | Adults, CP-CML, acquired hematologic resistance or intolerance to imatinib therapy, | 55 [18–84] (47) | CP 670 (100) | Imatinib resistance 491 (73); imatinib intolerance 171 (26) | NR | Imatinib 670 (100); IFN 349 (52); chemotherapy 175 (26); SCT 35 (5) | -4 groups: dasatinib 100 mg qd; 50 mg bid; 140mg qd; 70 mg bid -NR | NR [6-NR] c
Hochhaus, 2008 (Multinational) | -387 -Prospective multi-center phase II, open-label, single arm study -Unclear | Adults with CML-CP, imatinib resistant or intolerant | 58 [21–85] (49) | CP 387 (100) | Imatinib resistance 288 (74); imatinib intolerance 99 (26) | NR | Imatinib 387 (100); IFN 252 (65); chemotherapy 135 (35); allo-SCT 38 (10); radiotherapy 9 (2) | -Dasatinib70 mg bid -84% of the patients received treatment for >6mo - Median actual daily dose of dasatinib, 101 mg | 15 [NR]
Hochhaus, 2007 (Multinational) | -186^d^ -Prospective multi-center phase II, open-label, single arm study -Unclear | Adults with CML-CP, imatinib resistant or intolerant | 59 [24–79] (46) | CP, 186 (100) | Imatinib resistance 127 (68); imatinib intolerance 59 (32) | NR | Imatinib 186 (100); IFN 130 (70); SCT 17 (9) | -Dasatinib 70mg bid -Median actual daily dose of dasatinib, 101 mg | 8 [0–11]^e^
Quintas-Cardama, 2009^f^ (USA) | -293 -Retrospective analysis of 3 trials -Convenience sampling | CML-CP Participants of the previous dasatinib trials Imatinib failure (loss of MCyR or MCyR and CHR after achieving MCyR and CHR; or loss of CHR after achieving CHR only) | 57 [18–85] (54) | CP 293 (100) NR | Loss of MCyR 151 (52); loss of MCyR and CHR 33 (11); loss of CHR in no MCyR 109 (37) | NR | Imatinib 293 (100); IFN 197 (67); allogeneic SCT 25 (9) | -Dasatinib 100–180 mg/d -NR | 14 [0–31]^g^
Kantarjian, 2009 (USA) | -317 -Subgroup analysis of RCT -Unclear | CML AP Imatinib resistance or tolerance | 56 [17–84] (57) | AP 317 (100) | Imatinib resistance 233 (74); imatinib tolerance 84 (26) | NR | Imatinib ≤600 mg/d 176 (56); Imatinib >600 mg/d 141 (44); IFN 172 (54); others 140 (44); SCT 28 (9) | -Dasatinib 140 mg (once or in two divided dose)/d -NR | 15 [0–35]
Guilhot, 2006 (Multinational) | -107 -Prospective phase II, open-label, single arm study -Unclear | CML-AP with primary or acquired hematologic resistance or intolerance to imatinib | 57 [23–86] (51) | AP 107 (100) | Imatinib resistance 99 (93); imatinib intolerance 8 (8) | NR | Imatinib 107 (100); IFN 80 (75); chemotherapy 72 (67); SCT 19 (18); anagrelide 103 (96); radiotherapy 4 (4) typically | -Dasatinib 70 mg bid -NR | 8 [0–13]^h^
Cortes, 2008 (Multinational) | -157 -Combined analysis of 2 prospective, multi-center phase II, open label clinical trials (START-B and START-L) -Unclear | Imatinib resistant or intolerant myeloid (START-B) or lymphoid (START-L) BP-CML | START-B, 55 [21–81] (58) START-L, 50 [17–73] (52) | BP, 157 (100) | Imatinib resistance 141 (90) | NR | Imatinib 157 (100); IFN 76 (48); chemotherapy 103 (66); SCT 30 (19); radiotherapy 19 (12) | -Dasatinib 70 mg bid -Median duration of therapy, START-B, 3.5 mo; START-L, 2.9 mo Median average daily dose, START-B, 135 mg; START-L, 140 mg | 3 [0–21]
Cortes, 2007^i^ (Multinational) | -116 -Combined analysis of 2 prospective, multi-center phase II, open label clinical trials -Unclear | Imatinib resistant or intolerant myeloid (START-B) or lymphoid (START-L) BP-CML | START-B, 55 [21–71] (55) START-L, 47 [19–72] (52) | BP, 116 (100) | Imatinib resistance 105 (91); imatinib intolerance 11 (9) | NR | Imatinib 116 (100); IFN 61 (53); chemotherapy 82 (71); SCT 23 (20) | -Dasatinib 70 mg bid -Median average daily dose, START-B, 137mg; START-L, 140mg At 8 months 1 patient discontinued due to non-compliance | START-B, 4 [0–12]; START-L, 3 (0–9)^j^
Talpaz, 2006 (USA) | -79^k^ -Prospective multi-center phase I trial -Unclear | ≥18 y Ph+ CML (or ALL) | 56 [15–79] (56) | CP 40 (51); AP 11 (14); BC 28 (35) | Primary imatinib resistance 16 (19); acquired imatinib resistance 54 (64); intolerance to imatinib 12 (14) | ND | Imatinib 72 (86) | -Dasatinib 15–240 mg/d -NR | NR
Sakamaki, 2009 (Japan) | -41^l^ -Prospective multi-center phase I/II trial -Unclear | Imatinib resistant or intolerant Ph+ CML | 52 [27–73] (65) | CP 30 (73); AP/BC 11 (27) | Imatinib resistance 26 (63); imatinib intolerance 15 (37) | NR | Imatinib 41 (100); IFN 18 (44); others 40 (98); SCT 4 (10) NR | -Dasatinib 100–180 mg/d -Median dose ~98 mg/d | 21^m^
Wu, 2008^n^ (USA) | -18 -Retrospective analysis of phase I clinical trial -Convenience sampling | Patients with CML resistant or intolerant to imatinib treatment selected based on the availability of mononuclear cells and the lack of BCR-ABL kinase domain mutations^o^ | 55 [34–70] (39) | CP 11 (61); AP 1 (5); BP 6 (33) | Imatinib resistance 12 (67); imatinib intolerance 6 (33) | NR | Imatinib 18 (100); IFN 14 (78); HU 10 (56); chemotherapy other than HU 8 (44); homoharringtonine 5 (28); nilotinib 2 (11); farnesyltransferase inhibitor 2 (11); all-trans retinoic acid 2 (11) | -Dasatinib -NR | NR
Nilotinib
Kantarjian, 2007a (Multinational) | -280^p^ -Prospective multi-center phase II study -Convenience sampling | Adults with CML-CP, imatinib-resistant or intolerant | 58 [21–85] (51) | CP 280 (100) | Imatinib resistance 194 (69); imatinib intolerance 86 (31) | NR | Imatinib 280 (100); IFN 184 (66); HU 233 (83); cytarabine 71 (25); allogeneic or SCT 22 (8) | -Nilotinib 400mg bid -Median cumulative duration of nilotinib dose interruptions: 261 days [1–502] Median dose intensity: 797 mg/ day [151–1112] | NR^q^
Coutre, 2008 (Multiple countries) | -119 -Retrospective analysis of multicenter phase II trial -Convenience sampling | Imatinib-resistantr or - intolerant accelerated phase CML ≥18 y PS ≤2 (WHO) | 57 [22–79] (56) | AP 119 (100) | Resistance 96 (81); intolerance 23 (19) | NR | Imatinib 119 (100); HU 109 (92); IFN 69 (58); Cytarabine 31 (26) | -Nilotinib 800–1200 mg/d -Median dose intensity 790 mg/d (range, 180–1149) | 7 [0–20]^s^
Kantarjian, 2006^t^ (Multinational) | -106 -Prospective multi-center phase I study -Unclear | Adults with CML-AP, -BP or with CP in imatinib-resistant | NR | CP 17 (16); AP 56 (53); BP 33 (31) | Imatinib resistance 89 (84); imatinib intolerance 17 (16) | NR | NR | -Patients were assigned to one of nine cohorts receiving different nilotinib doses (from 50–1200mg qd and from 400–600 mg bid) -NR | NR
Miscellaneous
Kantarjian 2007b^u^ (Multinational) | -150 (101 in the dasatinib arm and 49 in the high-dose imatinib arm) -Prospective, multi-center phase II, open label, randomized (2:1) clinical -Unclear | CML-CP with primary or acquired resistance to conventional-dose (400–600mg) imatinib | Dasatinib arm, 51 [24–85] (52); Imatinib arm 51 [24–80] (45) | CP, 150 (100) | Imatinib resistance 150 (100) | NR | Dasatinib arm: hydroxyurea/anagrelide 97 (96); IFN 74 (73); chemotherapy 39 (39), SCT 7 (7). Imatinib arm: hydroxyurea/anagrelide 46 (94); IFN 33 (67); chemotherapy 18 (37), SCT 2 (4) | -Arm A: dasatinib, 70mg bid; Arm B: imatinib, 400 mg bid -NR | 15 [1–21]
Cortes, 2007 (USA) | -112 -Retrospective single-center cohort -Convenience sampling | Patients who failed or where intolerant to imatinib or second generation TKIS | 51 [17–96] (NR) | CP 38 (34); AP 54 (54); BP 20 (20) | Imatinib resistance 107 (96); imatinib intolerance 5 (4) | NR | Imatinib 112 (100); IFN 69 (62) | -Dasatinib 56 (50); nilotinib 54 (48); bosutinib 2 (2) -NR | 17 [4–31]^v^

a Duration of therapy

b 25 of the patients had previously received imatinib (3 were newly diagnosed).

c Median treatment duration was 8 months (<1 month – 15 moths).

d The full cohort results are presented in Hochhaus, 2008.

e Median duration of dasatinib treatment.

f The original cohort results are presented in Shah, 2008; Hochhaus, 2008; and Katarjian, 2007b.

g Duration of therapy

h Median duration of study therapy [range].

i The full cohort results are presented in Cortes, 2008.

j Median duration of therapy.

k Excluding 5 Ph+ ALL patients. Data on age, gender, and prior treatments were based on the entire population including 5 ALL patients.

l Excluding 13 Ph+ALL patients. Data on gender are based on the entire population including 13 ALL patients.

m Duration of therapy

n The full cohort results are presented in Talpaz, 2006.

o Other BCR-ABL mutations were allowed.

p Study enrolled 318 patients of whom 280 had at least 6 months of follow-up or had discontinued treatment and were included in this report.

q Median duration of exposure to nilotinib for the overall cohort (318 patients) was 245 days.

r Disease progression from chronic phase to accelerated phase (imatinib ≥600 mg/d); ≥50% increase in peripheral white blood cells, blasts, basophils, or platelets(imatinib ≥600 mg/d); lack of hematologic response after ≥4 wk (imatinib ≥600 mg/d); or presence of BCR-ABL mutation including L248, G250, Q252, Y253, E255, T315, F317, and H396 (imatinib <600 mg/d).

s Duration of therapy

t This report included 106 cases of CML and 13 cases of BCR-ABL positive ALL. We have only extracted data for CML patients.

u Patients with specific mutations (L248V, G250E, Q252H/R, Y253H/F, E255K/V, T315I/D, F317L, and H396P/R) known to be associated with imatinib resistance were excluded from the study.

v Time since second line TKI treatment initiation.

AP, accelerated phase; BP, blastic phase; BU, busulfan; CML, chronic myeloid leukemia; CHR, complete hematologic response; CP= chronic phase; CR, complete remission; CyR, cytogenetic response; Cr, creatinine; GMCSF, granulocyte-macrophage-colony-stimulating factor; HHT, (semisynthetic) homoharringtonine; HU, hydroxyurea; IFN, interferon-α; L-PAM, melphalan; MCyR, major cytogenetic response; NR, not reported; PS, performance status; SCT, stem cell transplantation; TBil, total bilirubin; 6TG, 6-thioguanine; TopoII, topoisomerase II inhibitor; WHO, World Health Organization.

##### Characteristics of mutation testing and mutation frequencies

BRC-ABL1 mutations are somatic mutations. The mutational profile of CML can therefore evolve in the various stages of CML. We describe characteristics of mutation testing in the included studies according to stage, namely chronic (Table 24), accelerated or blastic (Table 25) or any phase (Table 26). Typically, details on how frequently test samples were obtainable or how often mutation tests were successfully performed were not reported. Seventeen of 18 studies performed direct sequencing of the kinase domain of the BCR-ABL1 gene.(128;129;131–135;137;138;141–148) One study did not report technical specification of mutation tests in specific detail.(139) Three of 18 studies also performed denaturing high-performance liquid chromatography in addition to direct sequencing.(135;137;146) Rarely did studies report on tissue sources, how test samples were treated, durations between sampling and mutation tests, or detection sensitivity of the tests. The number of patients assessed for mutations ranged from18 to 563 (median, 112).

Studies reported various frequencies of mutations (Figure 13). Any mutations were detected at 24 to 59 percent for patients in the chronic phase, and 27 to 60 percent for accelerated or blastic phase. The T315I mutation was identified at up to 9 and 7 percent of patients in chronic phase and accelerated or blastic phase studies, respectively.

Table 24 BCR-ABL1 and tyrosine kinase inhibitors for CML: technical specification of mutation testing and frequency of identified mutations (chronic phase)

Study (first author, year) | Assessed patients, n (% of included patients) | Staging | Mutation detection method | Source (Tube) [process and time between collection and RNA extraction, h] | Detection sensitivity (%) | Mutation Frequency, n (%)
Study (first author, year) | Assessed patients, n (% of included patients) | Staging | Mutation detection method | Source (Tube) [process and time between collection and RNA extraction, h] | Detection sensitivity (%) | Mutation + | Mutation −
High-dose Imatinib
Kantarjian, 2007b^a^ | 138 (92) | CP | DS | NR | NR | Any 11 (24) T315I NR | 35 (76)
Jabbour, 2009 | 25 (30) | CP | DS | NR | NR | Any 8 (32) T315I 0 | 17 (68)
Imatinib-based Combination Chemotherapy
Cortes, 2007a | 25 (96) | CP | DS | NR | NR | Any 13 (52) T315I 1 (4) | 12 (48)
Dasatinib
Shah, 2008 | 563 (84)^b^ | CP | DHPLC; DS | PB (NR) [NR] | NR | Any 205(36) | 358 (64)
Hochhaus, 2008 | 345 (89) | CP | NR | NR | NR | Any 139 (40) T315I 3 (9) | 206 (60)
Hochhaus, 2007^c^ | 180 (97) | CP | DHPLC; DS | PB [NR] | NR | Any 73 (41) T315I 3 (2) | 107 (59)
Quintas-Carddama, 2009 | 268 (91) | CP | DS | NR | NR | Any 157 (59) T315I 4 (1) | 111 (41)
Kantarjian, 2007b^d^ | 138 (92) | CP | DS | NR | NR | Any 41 (45) T315I NR | 51 (55)
Nilotinib
Kantarjian, 2007a | 182 (65) | CP | DS | PB (NR) [NR] | 20 | Any 77 (42) T315I 4 (2) | 105 (58)

a Patients with specific mutations (L248V, G250E, Q252H/R, Y253H/F, E255K/V, T315I/D, F317L, and H396P/R) known to be associated with imatinib resistance were excluded from the study.

b 7 samples were not assessed successfully.

c Six individuals had mutations identified “at the site prior to study entry” and were excluded from the report due to lack of confirmation by the study central laboratory.

d Patients with specific mutations (L248V, G250E, Q252H/R, Y253H/F, E255K/V, T315I/D, F317L, and H396P/R) known to be associated with imatinib resistance were excluded from the study.

BM, bone marrow; DHPLC, denaturing high-performance liquid chromatography; DS, direct sequencing; PB, peripheral blood.

Table 25 BCR-ABL1 and tyrosine kinase inhibitors for CML: technical specification mutation testing and frequency of detected mutations (accelerated or blastic phase)

Study (first author, year) | Assessed patients, n (% of included patients) | Staging | Mutation detection method | Source (Tube) [process and time between collection and RNA extraction, h] | Detection sensitivity (%) | Mutation Frequency, n (%)
Study (first author, year) | Assessed patients, n (% of included patients) | Staging | Mutation detection method | Source (Tube) [process and time between collection and RNA extraction, h] | Detection sensitivity (%) | Mutation + | Mutation −
Imatinib-based Combination Chemotherapy
Oki, 2006 | 26 (89) | AP/BP | DS | PB/BM (NR) [NR] | NR | Any 7 (27) T315I 1 (4) | 19 (73)
Dasatinib
Kantarjian, 2009 | 292 (92) | AP | DS | NR | NR | Any 136 (47) T315I 20 (7) | 156 (53)
Guilhot, 2006 | 100 (93) | AP | NR^a^ | NR | NR | Any 60 (60) T315I 5 (5) | 40 (40)
Cortes, 2008 | 144 (92) | BP | NR | NR | NR | Any 71 (49) T315I 10 (7) | 73 (51)
Cortes, 2007c | 110 (95)^b^ | BP | DS | PB [NR] | NR | Any 54 (49) T315I 8 (7) | 56 (51)
Nilotinib
Kantarjian, 2006 | 86 (81) | AP | DS | PB (NR) [NR] | NR | Any 37 (43) T315I 2 (2) | 49 (57)

a “Exploratory assays”.

b Mutation assessment was not performed at base line for 2/42 patients with available samples.

BM, bone marrow; DHPLC, denaturing high-performance liquid chromatography; DS, direct sequencing; PB, peripheral blood

Table 26 BCR-ABL1 and tyrosine kinase inhibitors for CML: technical specification of mutation testing and frequency of detected mutations (miscellaneous phases)

Study (first author, year) | Assessed patients, n (% of included patients) | Staging | Mutation detection method | Source (Tube) [process and time between collection and RNA extraction, h] | Detection sensitivity (%) | Mutation Frequency, n (%)
Study (first author, year) | Assessed patients, n (% of included patients) | Staging | Mutation detection method | Source (Tube) [process and time between collection and RNA extraction, h] | Detection sensitivity (%) | Mutation + | Mutation −
Imatinib-based Combination Chemotherapy
Cortes, 2007b | 21 (91) | Any | DS | NR | NR | Any 11 (52) T315I NR | 10 (48)
Dasatinib
Talpaz, 2006 | 79 (100) | Any | DS | NR | NR | Any 56^a^ (71) T315I 7 (9) | 23 (29)
Sakamaki, 2009 | 41 (100) | Any | NR | NR | NR | Any 7 (17) T315I 1 (2)^b^ | 34 (83)
Wu, 2008 | 18 (100) | Any | DS | PB/BM (NR) [NR] | NR | Any 3 (17) T315I 0 | 15 (83)
Nilotinib
Coutre, 2008 | 51 (43) | Any | DHPLC + DS | PB (NR) [NR] | 20 | Any 29 (57) T315I 2 (7) | 22 (43)
Miscellaneous
Cortes, 2007d | 112 (100) | Any | DS | PB/BM (NR) [NR] | 10–20 | Any 61 (54) T315I 10 (<1) | 51 (46)

a 29 patients had multiple mutations

b This number is based on the entire population including 13 acute lymphoblastic leukemia patients.

BM, bone marrow; DHPLC, denaturing high-performance liquid chromatography; DS, direct sequencing; PB, peripheral blood.

###### Association of BCR-ABL1 mutation test results and mortality

No study evaluated overall survival.

###### Association of BCR-ABL1 testing results and disease progression outcomes

A single study (Jabbour 2009, median followup 61 months) evaluated event-free survival (defined as loss of partial or complete hematologic response, major cytogenetic response, progression to accelerated or blastic phase, or death from any causes) and transformation-free survival (defined as progression to accelerated or blastic phase, or death from any causes) in 25 patients treated with high-dose imatinib as second line TKI therapy.(131) The study found no statistically significant differences in the time-to-event among patients with versus without mutations (for all assessed mutations, hazard ratio not reported; log rank p=0.96 and 0.51 for event-free and transformation-free survival, respectively). The study found no patients with the T315I mutation but assessed only 30% of the entire patient cohort for the presence of mutations.

###### Ability of BCR-ABL1 mutation testing to predict TKI treatment failure in hematologic response

In total 16 studies published in 17 publications reported relevant data.(129;129;132–139;142–148) Studies defined treatment failure in non-uniform ways. Two most commonly employed definitions were absence of complete hematologic response or absence of major hematologic response. The latter was defined as absence of complete hematologic response or evidence of leukemia. Only three studies(129;139;141) give details on the timing of patient failure assessments. Table 27, Figure 14, and Figure 15 summarize sensitivities, specificities and likelihood ratios of any mutation or the T315I mutation to predict absence of hematologic response.

When any BCR-ABL1 mutation was considered (Figure 14), almost all studies reported sensitivity and specificity values that are not suggestive of strong predictive ability (i.e., they fall near or below the diagonal line in the plots). Most studies do not fall on areas suggestive of high positive or low negative likelihood ratios and the few that do have small sample sizes and sparse numbers (Table 27). The following observations can be made for studies of different treatment types when it comes to the presence of any mutation, regardless of disease stage:

- The 4 high-dose imatinib and imatinib-based combination studies were all above the diagonal, with sensitivity and specificity ranging from 0.35 to 0.83 and from 0.58 to 1.00, respectively.(129;132–134) However, these studies are small, the calculated sensitivity and specificity values have wide confidence intervals, and a range of different mutations was identified in each of them. Therefore, no robust conclusions can be made.
- Eight studies (9 publications(129;135–139;142–144)) pertained to dasatinib. As shown in Figure 12 some have overlapping populations. Sensitivities and specificities ranged widely from 0.27 to 0.90 and from 0.14 to 0.87, respectively. However, studies were very near or on the diagonal, suggesting lack of predictive ability.
- For nilotinib, three studies had relevant data.(145–147) Sensitivity ranged from 0.56 to 0.71 and specificity ranged from 0.42 to 0.56 for all identified mutations.

When we considered the T315I mutation (Figure 15) the general pattern is different. Again, the majority of data pertain to dasatinib treated patients. Across all treatment types, the majority of studies are located in an area of the plot suggestive of high positive likelihood ratio, with high specificity values, albeit low sensitivity values. This implies that presence of the relatively rare T315I mutation is strongly predictive of hematologic failure. Because the T315I mutation is relatively rare, the confidence intervals of the calculated sensitivity and specificity values are wide (Table 27).

Table 27 BCR-ABL1 and tyrosine kinase inhibitors for CML: treatment failure (hematologic response

Author, year | Stage | Definition of Response (Criteria) | BCR-ABL1 mutations | Patient, n | | | | Sensitivity (95%CI) | Specificity (95%CI) | LR+ | LR−
Author, year | Stage | Definition of Response (Criteria) | BCR-ABL1 mutations | Mutation + | | Mutation − | | Sensitivity (95%CI) | Specificity (95%CI) | LR+ | LR−
Author, year | Stage | Definition of Response (Criteria) | BCR-ABL1 mutations | TP | FP | FN | TN | Sensitivity (95%CI) | Specificity (95%CI) | LR+ | LR−
High-dose Imatinib
Kantarjian, 2007b^a^ | CP | CHR (Talpaz NEJM 2006) | All identified mutations | 5 | 6 | 3 | 32 | 0.63 (0.24, 0.91) | 0.84 (0.69, 0.94) | 3.96 | 0.45
Kantarjian, 2007b^a^ | CP | CHR (Talpaz NEJM 2006) | T315I | NR | NR | NR | NR | NR | NR | NR | NR
Imatinib-based Combination
Cortes, 2007a | CP | HR (Kantarjian Ann Intern Med 1995) | All identified mutations | 5 | 8 | 1 | 11 | 0.83 (0.36, 1.00) | 0.58 (0.33, 0.80) | 1.98 | 0.29
Cortes, 2007a | CP | HR (Kantarjian Ann Intern Med 1995) | T315I | 0 | 1 | 6 | 18 | 0.00 (0.00, 0.46) | 0.95 (0.74, 1.00) | <0.01 | 1.06
Oki, 2006 | AP/BP | CHR (ELN) | All identified mutations | 6 | 1 | 11 | 8 | 0.35 (0.14, 0.62) | 0.89 (0.52, 1.00) | 3.18 | 0.73
Oki, 2006 | AP/BP | CHR (ELN) | T315I | NR | NR | NR | NR | NR | NR | NR | NR
Cortes, 2007b | Any | CHR (Kantarjian Ann Intern Med 1995) | All identified mutations | 11 | 0 | 9 | 1 | 0.55 (0.32, 0.77) | 1.00 (0.03, 1.00) | >100 | 0.45
Cortes, 2007b | Any | CHR (Kantarjian Ann Intern Med 1995) | T315I | NR | NR | NR | NR | NR | NR | NR | NR
Dasatinib
Shah, 2008 | CP | CHR (ELN) | All identified mutations | 27 | 178 | 29 | 29 | 0.48 (0.35, 0.62) | 0.14 (0.10, 0.19) | 0.56 | 3.7
Shah, 2008 | CP | CHR (ELN) | T315I | NR | NR | NR | NR | NR | NR | NR | NR
Hochhaus, 2008 | CP | CHR (ELN) | All identified mutations | 11 | 128 | 19 | 187 | 0.37 (0.20, 0.56) | 0.59 (0.54, 0.65) | 0.9 | 1.07
Hochhaus, 2008 | CP | CHR (ELN) | T315I | 3 | 0 | 27 | 315 | 0.10 (0.02, 0.27) | 1.00 (0.99, 1.00) | >100 | 0.9
Hochhaus, 2007 | CP | CHR (ELN) | All identified mutations | 8 | 65 | 9 | 98 | 0.47 (0.23, 0.72) | 0.60 (0.52, 0.68) | 1.18 | 0.88
Hochhaus, 2007 | CP | CHR (ELN) | T315I | 3 | 0 | 14 | 163 | 0.18 (0.04, 0.43) | 1.00 (0.98, 1.00) | >100 | 0.82
Kantarjian, 2007^b^ | CP | CHR (Talpaz NEJM 2006) | All identified mutations | 5 | 36 | 1 | 50 | 0.83 (0.36, 1.00) | 0.58 (0.47, 0.69) | 1.99 | 0.29
Kantarjian, 2007^b^ | CP | CHR (Talpaz NEJM 2006) | T315I | NR | NR | NR | NR | NR | NR | NR | NR
Kantarjian, 2009 | AP | Major HR (Guilhot Blood 2007) | All identified mutations | 47 | 89 | 49 | 107 | 0.49 (0.39, 0.59) | 0.55 (0.47, 0.62) | 1.08 | 0.93
Kantarjian, 2009 | AP | Major HR (Guilhot Blood 2007) | T315I | 9 | 2 | 87 | 194 | 0.09 (0.04, 0.17) | 0.99 (0.96, 1.00) | 9.19 | 0.92
Guilhot, 2006 | AP | Major HR (Guilhot Blood 2006) | All identified mutations | 16 | 44 | 18 | 22 | 0.47 (0.30, 0.65) | 0.33 (0.22, 0.46) | 0.71 | 1.59
Guilhot, 2006 | AP | Major HR (Guilhot Blood 2006) | T315I | 5 | 0 | 29 | 66 | 0.15 (0.05, 0.31) | 1.00 (0.95, 1.00) | >100 | 0.85
Talpaz, 2006 | Any | HR (Talpaz NEJM 2006) | All identified mutations | 9 | 47 | 1 | 22 | 0.90 (0.55, 1.00) | 0.32 (0.21, 0.44) | 1.32 | 0.31
Talpaz, 2006 | Any | HR (Talpaz NEJM 2006) | T315I | 3 | 0 | 7 | 69 | 0.30 (0.07, 0.65) | 1.00 (0.95, 1.00) | >100 | 0.7
Talpaz, 2006 | Any | Major HR (Talpaz NEJM 2006) | All identified mutations | 11 | 45 | 3 | 20 | 0.79 (0.49, 0.95) | 0.31 (0.20, 0.43) | 1.13 | 0.7
Talpaz, 2006 | Any | Major HR (Talpaz NEJM 2006) | T315I | 3 | 0 | 11 | 65 | 0.21 (0.05, 0.51) | 1.00 (0.94, 1.00) | >100 | 0.79
Talpaz, 2006 | Any | CHR (Talpaz NEJM 2006) | All identified mutations | 16 | 40 | 8 | 15 | 0.67 (0.45, 0.84) | 0.27 (0.16, 0.41) | 0.92 | 1.22
Talpaz, 2006 | Any | CHR (Talpaz NEJM 2006) | T315I | 3 | 0 | 21 | 55 | 0.13 (0.03, 0.32) | 1.00 (0.94, 1.00) | >100 | 0.88
Sakamaki, 2009 | Any | Major HR (Talpaz NEJM 2006) | All identified mutations | 3 | 4 | 8 | 26 | 0.27 (0.06, 0.61) | 0.87 (0.69, 0.96) | 2.05 | 0.84
Sakamaki, 2009 | Any | Major HR (Talpaz NEJM 2006) | T315I | NR | NR | NR | NR | NR | NR | NR | NR
Wu, 2008 | Any | CHR (Talpaz NEJM 2006) | All identified mutations | 0 | 3 | 0 | 15 | NE | 0.83 (0.59, 0.96) | NE | NE
Wu, 2008 | Any | CHR (Talpaz NEJM 2006) | T315I | NR | NR | NR | NR | NR | NR | NR | NR
Nilotinib
Kantarjian, 2007a | CP | CHR^c^ (Kantarjian NEJM 2002) | All identified mutations | 24 | 38 | 10 | 48 | 0.71 (0.53, 0.85) | 0.56 (0.45, 0.67) | 1.6 | 0.53
Kantarjian, 2007a | CP | CHR^c^ (Kantarjian NEJM 2002) | T315I | 4 | 0 | 30 | 86 | 0.12 (0.03, 0.27) | 1.00 (0.96, 1.00) | >100 | 0.88
Kantarjian, 2006 | AP | HR (Kantarjian NEJM 2002) | All identified mutations | 14 | 23 | 20 | 29 | 0.41 (0.25, 0.59) | 0.56 (0.41, 0.70) | 0.93 | 1.05
Kantarjian, 2006 | AP | HR (Kantarjian NEJM 2002) | T315I | 2 | 0 | 32 | 52 | 0.06 (0.01, 0.20) | 1.00 (0.93, 1.00) | >100 | 0.94
Coutre, 2008 | Any | Major HR + return to chronic phase^d^ (ELN) | All identified mutations | 15 | 14 | 12 | 10 | 0.56 (0.35, 0.75) | 0.42 (0.22, 0.63) | 0.95 | 1.07
Coutre, 2008 | Any | Major HR + return to chronic phase^d^ (ELN) | T315I | 0 | 1 | 27 | 23 | 0.00 (0.00, 0.13) | 0.96 (0.79, 1.00) | <0.01 | 1.04
Miscellaneous
Cortes, 2007d | Any | Major HR HR (Kantarjian NEJM 2002) | All identified mutations | 16 | 45 | 11 | 40 | 0.59 (0.39, 0.78) | 0.47 (0.36, 0.58) | 1.12 | 0.87
Cortes, 2007d | Any | Major HR HR (Kantarjian NEJM 2002) | T315I | 8 | 2 | 19 | 83 | 0.30 (0.14, 0.50) | 0.98 (0.92, 1.00) | 12.59 | 0.72
Major HR

a Patients with specific mutations (L248V, G250E, Q252H/R, Y253H/F, E255K/V, T315I/D, F317L, and H396P/R) known to be associated with imatinib resistance were excluded from the study.

b 12 patients had no mutational analysis performed at baseline (9 from the dasatinib arm and 3 from the imatinib arm).

c CHR is reported only for patients who did not have CHR at study entry.

d Applicable only to accelerated and blastic phase.

Figure 14 BCR-ABL1 and tyrosine kinase inhibitors for CML: receiver operating characteristic (ROC) plotting for treatment failure (hematologic response, all mutations)

Individual study estimates of sensitivity and 100-specificity (%) regardless of different definitions of failure in hematologic response are shown. “Imatinib-based” includes high dose imatinib and imatinib-based combination. See the method section for the definition of treatment categories. Abbreviations: AP = accelerated phase; BP = blastic phase; CP = chronic phase

Figure 14. BCR-ABL1 and tyrosine kinase inhibitors for CML: receiver operating characteristic (ROC) plotting for treatment failure (hematologic response, all mutations). (page 111) Individual study estimates of sensitivity and 100-specificity (%) regardless of different definitions of failure in hematologic response are shown. “Imatinib-based” includes high dose imatinib and imatinib-based combination. See the method section for the definition of treatment categories. In all but the imatitinib-based studies graph, the majority of studies lay on the diagonal. In the imatinib-based studies graph the studies appear to have somewhat higher sensitivity and specificity although data are sparse.

Figure 15 BCR-ABL1 and tyrosine kinase inhibitors for CML: receiver operating characteristic (ROC) plotting to predict treatment failure (hematologic response, T315I mutations)

Individual study estimates of sensitivity and 100-specificity (%) regardless of different definitions of failure in hematologic response are shown. “Imatinib-based” includes high dose imatinib and imatinib-based combination. See the method section for the definition of treatment categories. Abbreviations: AP = accelerated phase; BP = blastic phase; CP = chronic phase

Figure 15. BCR-ABL1 and tyrosine kinase inhibitors for CML: receiver operating characteristic (ROC) plotting to predict treatment failure (hematologic response, T315I mutations). (page 112) Individual study estimates of sensitivity and 100-specificity (%) regardless of different definitions of failure in hematologic response are shown. Four plots are shown (clockwise from top left): imatinib-based treatments, dasatinib, nilotinib and "miscelaneous".“Imatinib-based” includes high dose imatinib and imatinib-based combination. See the method section for the definition of treatment categories. The graphs indicate that T315I has high specificity and low sensitivity (the studies cluster in the botom left corner of each graph).

###### Ability of BCR-ABL1 mutation testing to predict TKI treatment failure (no cytogenetic response)

In total 18 studies in 20 publications reported relevant data.(128;129;129;129;131–133;135–147) Studies defined treatment failure in non-uniform ways. Two most commonly employed definitions were absence of complete cytogenetic response or absence of major cytogenetic response. The latter was defined as absence of at least partial cytogenetic response. Only three studies(129;139;141) give details on the timing of patient failure assessments. Table 28, Figure 16, and Figure 17 summarize sensitivities, specificities and likelihood ratios of any mutation or the T315I mutation to predict absence of cytogenetic response.

When any BCR-ABL1 mutation was considered (Figure 16), almost all studies reported sensitivity and specificity values that are not suggestive of strong predictive ability (i.e., they fall near or below the diagonal line in the plots). Most studies do not fall on areas suggestive of high positive or low negative likelihood ratios and the few that do have small sample sizes and sparse numbers (Table 28). The following observations can be made for studies of different treatment types when it comes to the presence of any mutation, regardless of disease stage:

- The 4 high-dose imatinib and imatinib-based combination studies were scattered throughout the plot, with sensitivity and specificity ranging from 0.33 to 1.00 and from 0.56 to 1.00, respectively.(129;131–133) Two studies lie on regions suggestive of high positive or low negative likelihood ratios. However, these studies are small, the calculated sensitivity and specificity values have wide confidence intervals, and a range of different mutations was identified in each of them.
- Ten studies (12 publications(129;135–139;142–144)) pertained to dasatinib. As shown in Figure 12 some have overlapping populations. Sensitivities and specificities ranged widely from 0 to 0.76 and from 0.33 to 0.87, respectively. However, studies were near or on the diagonal, suggesting lack of predictive ability.
- For nilotinib, three studies had relevant data.(145–147) Sensitivity ranged from 0.40 to 0.62 and specificity ranged from 0.54 to 0.59.

When we considered the T315I mutation (Figure 17) the general pattern is different. Again, the majority of data pertain to dasatinib treated patients. Across all treatment types, the majority of studies are located in an area of the plot suggestive of high positive likelihood ratio, with high specificity values, albeit low sensitivity values. This implies that presence of the relatively rare T315I mutation is strongly predictive of at least cytogenetic failure. Because the T315I mutation is relatively rare, the confidence intervals of the calculated sensitivity and specificity values are wide (Table 28).

Table 28 BCR-ABL1 and tyrosine kinase inhibitors for CML: treatment failure (cytogenetic response)

Author, year | Stage | Response criteria | BCR-ABL1 mutations | Patient, n | | | | Sensitivity (95%CI) | Specificity (95%CI) | LR+ | LR−
Author, year | Stage | Response criteria | BCR-ABL1 mutations | Mutation + | | Mutation − | | Sensitivity (95%CI) | Specificity (95%CI) | LR+ | LR−
Author, year | Stage | Response criteria | BCR-ABL1 mutations | TP | FP | FN | TN | Sensitivity (95%CI) | Specificity (95%CI) | LR+ | LR−
High-dose Imatinib
Kantarjian, 2007b^a^ | CP | Major CyR (ELN) | All identified mutations | 8 | 3 | 23 | 12 | 0.26 (0.12, 0.45) | 0.80 (0.52, 0.96) | 1.29 | 0.93
| | | T315I | 2 | 1 | 29 | 14 | 0.06 (0.01, 0.21) | 0.93 (0.68, 1.00) | 0.97 | 1
Jabbour, 2009 | CP | Major CyR | All identified mutations | 2 | 6 | 0 | 17 | 1.00 (0.16, 1.00) | 0.74 (0.52, 0.90) | 3.83 | <0.01
| | | T315I | 0 | 0 | 2 | 23 | 0.00 (0.00, 0.84) | 1.00 (0.85, 1.00) | >100 | 1
Imatinib-based Combination
Cortes, 2007a | CP | CyR (ELN) | All identified mutations | 9 | 4 | 7 | 5 | 0.56 (0.30, 0.80) | 0.56 (0.21, 0.86) | 1.27 | 0.79
| | | T315I | 0 | 1 | 16 | 8 | 0.00 (0.00, 0.21) | 0.89 (0.52, 1.00) | <0.01 | 1.13
Oki, 2006 | AP/BP | Major CyR | All identified mutations | 7 | 0 | 14 | 8 | 0.33 (0.15, 0.57) | 1.00 (0.63, 1.00) | >100 | 0.67
| | | T315I | NR | NR | NR | NR | NR | NR | NR | NR
Dasatinib
Shah, 2008 | CP | Major CyR | All identified mutations | 116 | 89 | 138 | 220 | 0.46 (0.39, 0.52) | 0.71 (0.66, 0.76) | 1.59 | 0.76
| | | T315I | NR | NR | NR | NR | NR | NR | NR | NR
Hochhaus, 2008 | CP | Major CyR | All identified mutations | 59 | 80 | 83 | 123 | 0.42 (0.33, 0.50) | 0.61 (0.54, 0.67) | 1.05 | 0.96
| | | T315I | 3 | 0 | 139 | 203 | 0.02 (0.00, 0.06) | 1.00 (0.98, 1.00) | >100 | 0.98
Hochhaus, 2007 | CP | Major CyR | All identified mutations | 37 | 36 | 49 | 58 | 0.43 (0.32, 0.54) | 0.62 (0.51, 0.72) | 1.12 | 0.92
| | | T315I | 3 | 0 | 83 | 94 | 0.03 (0.01, 0.10) | 1.00 (0.96, 1.00) | >100 | 0.97
Quintas-Cardama, 2009 | CP | CCyR (ELN) | All identified mutations | 83 | 74 | 47 | 64 | 0.64 (0.55, 0.72) | 0.46 (0.38, 0.55) | 1.19 | 0.78
| | | T315I | 4 | 0 | 126 | 138 | 0.03 (0.01, 0.08) | 1.00 (0.97, 1.00) | >100 | 0.97
Kantarjian, 2007b^b^ | CP | Major CyR (ELN) | All identified mutations | 22 | 19 | 23 | 28 | 0.49 (0.34, 0.64) | 0.60 (0.44, 0.74) | 1.21 | 0.86
| | | T315I | 2 | 1 | 43 | 46 | 0.04 (0.01, 0.15) | 0.98 (0.89, 1.00) | 2.09 | 0.98
Kantarjian, 2009 | AP | Major CyR (ELN) | All identified mutations | 89 | 47 | 90 | 66 | 0.50 (0.42, 0.57) | 0.58 (0.49, 0.68) | 1.2 | 0.86
| | | T315I | 11 | 0 | 168 | 113 | 0.06 (0.03, 0.11) | 1.00 (0.97, 1.00) | >100 | 0.94
Guilhot, 2006 | AP | Major CyR (ELN) | All identified mutations | 12 | 18 | 25 | 15 | 0.32 (0.18, 0.50) | 0.45 (0.28, 0.64) | 0.59 | 1.49
| | | T315I | 5 | 0 | 32 | 33 | 0.14 (0.05, 0.29) | 1.00 (0.89, 1.00) | >100 | 0.86
Cortes, 2008 | BP | Major CyR (ELN) | All identified mutations | 46 | 25 | 44 | 29 | 0.51 (0.40, 0.62) | 0.54 (0.40, 0.67) | 1.1 | 0.91
| | | T315I | 10 | 0 | 80 | 54 | 0.11 (0.05, 0.19) | 1.00 (0.93, 1.00) | >100 | 0.89
Cortes, 2007c | BP | Major CyR (ELN) | All identified mutations | 36 | 18 | 31 | 25 | 0.54 (0.41, 0.66) | 0.58 (0.42, 0.73) | 1.28 | 0.8
| | | T315I | 8 | 0 | 59 | 43 | 0.12 (0.05, 0.22) | 1.00 (0.92, 1.00) | >100 | 0.88
Talpaz, 2006 | Any | Major CyR (ELN) | All identified mutations | 34 | 22 | 11 | 12 | 0.76 (0.60, 0.87) | 0.35 (0.20, 0.54) | 1.17 | 0.69
| | | T315I | 3 | 0 | 42 | 34 | 0.07 (0.01, 0.18) | 1.00 (0.90, 1.00) | >100 | 0.93
| | CCyR (ELN) | All identified mutations | 40 | 16 | 15 | 8 | 0.73 (0.59, 0.84) | 0.33 (0.16, 0.55) | 1.09 | 0.82
| | | T315I | 3 | 0 | 52 | 24 | 0.05 (0.01, 0.15) | 1.00 (0.86, 1.00) | >100 | 0.95
Sakamaki, 2009 | Any | Major CyR (ELN) | All identified mutations | 4 | 3 | 14 | 20 | 0.22 (0.06, 0.48) | 0.87 (0.66, 0.97) | 1.7 | 0.89
| | | T315I | NR | NR | NR | NR | NR | NR | NR | NR
Wu, 2008 | Any | Major CyR (ELN) | All identified mutations | 0 | 3 | 8 | 7 | 0.00 (0.00, 0.37) | 0.70 (0.35, 0.93) | <0.01 | 1.43
| | | T315I | NR | NR | NR | NR | NR | NR | NR | NR
Nilotinib
Kantarjian, 2007a | CP | Major CyR (ELN) | All identified mutations | 45 | 32 | 67 | 38 | 0.40 (0.31, 0.50) | 0.54 (0.42, 0.66) | 0.88 | 1.1
| | | T315I | 4 | 0 | 108 | 70 | 0.04 (0.01, 0.09) | 1.00 (0.95, 1.00) | >100 | 0.96
Kantarjian, 2006 | AP | CyR^c^ (ELN) | All identified mutations | 19 | 18 | 23 | 26 | 0.45 (0.30, 0.61) | 0.59 (0.43, 0.74) | 1.11 | 0.93
| | | T315I | 0 | 0 | 42 | 44 | 0.00 (0.00, 0.08) | 1.00 (0.92, 1.00) | NE | 1
Coutre, 2008 | Any | Major CyR (ELN) | All identified mutations | 23 | 6 | 14 | 8 | 0.62 (0.45, 0.78) | 0.57 (0.29, 0.82) | 1.45 | 0.66
| | | T315I | 1 | 0 | 36 | 14 | 0.03 (0.00, 0.14) | 1.00 (0.77, 1.00) | >100 | 0.97
Miscellaneous
Cortes, 2007d | Any | CyR (ELN) | All identified mutations | 37 | 24 | 29 | 22 | 0.56 (0.43, 0.68) | 0.48 (0.33, 0.63) | 1.07 | 0.92
| | | T315I | 10 | 0 | 56 | 46 | 0.15 (0.08, 0.26) | 1.00 (0.92, 1.00) | >100 | 0.85
| | CCyR (ELN) | All identified mutations | 41 | 20 | 37 | 14 | 0.53 (0.41, 0.64) | 0.41 (0.25, 0.59) | 0.89 | 1.15
| | | T315I | 10 | 0 | 68 | 34 | 0.13 (0.06, 0.22) | 1.00 (0.90, 1.00) | >100 | 0.87

a Patients with specific mutations (L248V, G250E, Q252H/R, Y253H/F, E255K/V, T315I/D, F317L, and H396P/R) known to be associated with imatinib resistance were excluded from the study.

b 12 patients had no mutational analysis performed at baseline (9 from the dasatinib arm and 3 from the imatinib arm).

c Defined as minimal, minor, major, and complete CyR

Figure 16 BCR-ABL1 and tyrosine kinase inhibitors for CML: receiver operating characteristic (ROC) plotting to predict treatment failure (cytogenetic response, all mutation)

Individual study estimates of sensitivity and 100-specificity (%) regardless of different definitions of failure in cytogenetic response are shown. “Imatinib-based” includes high dose imatinib and imatinib-based combination. See the method section for the definition of treatment categories. Abbreviations: AP = accelerated phase; BP = blastic phase; CP = chronic phase

Figure 16. BCR-ABL1 and tyrosine kinase inhibitors for CML: receiver operating characteristic (ROC) plotting to predict treatment failure (cytogenetic response, all mutation). (page 117) Individual study estimates of sensitivity and 100-specificity (%) regardless of different definitions of failure in cytogenetic response are shown. Four plots are shown (clockwise from top left): imatinib-based treatments, dasatinib, nilotinib and "miscelaneous". “Imatinib-based” includes high dose imatinib and imatinib-based combination. See the method section for the definition of treatment categories. In all four graphs, the majority of studies lay on the diagonal.

Figure 17 BCR-ABL1 and tyrosine kinase inhibitors for CML: receiver operating characteristic (ROC) plotting to predict treatment failure (cytogenetic response, T315I mutation)

Individual study estimates of sensitivity and 100-specificity (%) regardless of different definitions of failure in cytogenetic response are shown. “Imatinib-based” includes high dose imatinib and imatinib-based combination. See the method section for the definition of treatment categories. Abbreviations: AP = accelerated phase; BP = blastic phase; CP = chronic phase

Figure 17. BCR-ABL1 and tyrosine kinase inhibitors for CML: receiver operating characteristic (ROC) plotting to predict treatment failure (cytogenetic response, T315I mutation). (page 118) Individual study estimates of sensitivity and 100-specificity (%) regardless of different definitions of failure in cytogenetic response are shown for studies evaluating the ability of T315I mutation to predicit lack of response. Four plots are shown (clockwise from top left): imatinib-based treatments, dasatinib, nilotinib and "miscelaneous". “Imatinib-based” includes high dose imatinib and imatinib-based combination. See the method section for the definition of treatment categories. The graphs indicate that T315I has high specificity and low sensitivity (the studies cluster in the botom left corner of each graph).

###### Ability of BCR-ABL1 mutation testing to predict TKI treatment failure for molecular response

Only Quintas-Cardama 2009 evaluated major molecular response (defined as ratio of BCR-ABL1 to ABL1 gene less than 0.1%) in 108 patients treated with dasatinib as second line TKI therapy (Table 29).(128) Estimated sensitivity was 0.69 and specificity 0.43 to predict failure in achieving molecular response.

Table 29 BCR-ABL1 and tyrosine kinase inhibitors for CML: treatment failure (molecular response)

Author, year | Stage | Response criteria | BCR-ABL1 mutations | Patient, n | | | | Sensitivity (95%CI) | Specificity (95%CI) | LR+ | LR−
Author, year | Stage | Response criteria | BCR-ABL1 mutations | Mutation + | | Mutation − | | Sensitivity (95%CI) | Specificity (95%CI) | LR+ | LR−
Author, year | Stage | Response criteria | BCR-ABL1 mutations | TP | FP | FN | TN | Sensitivity (95%CI) | Specificity (95%CI) | LR+ | LR−
Dasatinib
Quintas-Cardama, 2009 | CP | Major MolR (ELN) | All identified mutations | 44 | 25 | 20 | 19 | 0.69 (0.56, 0.80) | 0.43 (0.28, 0.59) | 1.21 | 0.72
Quintas-Cardama, 2009 | CP | Major MolR (ELN) | T315I | NR | NR | NR | NR | NR | NR | NR | NR

CI, confidence interval; ENL, European Leukemia Net criteria compatible; Major MolR, major molecular response (defined as Ratio of BCR-ABL1 to ABL1 gene ≤0.1%);

#### Third line TKI therapy studies

One included study pertained to the use of dasatinib as third line therapy.(149) This study consisted of 23 patients with CML refractory to imatinib and nilotinib. It is likely that at least several patients in this study were included in at least some second line therapy studies (see legend of Figure 12).

The majority of subjects had CML in the accelerated or blastic phase with a median tumor load of 72 percent (Table 30). Direct sequencing was performed on all but one patient. Sixteen patients had at least one detected mutation in BCR-ABL1. The T315I mutation was detected in two patients. There were 7 mutations in the P-loop region, and 2 mutations each in the C-loop and A-loop regions of the BCR-ABL1 fusion protein.

##### Association of BCR-ABL1 mutation test results and mortality

The study did not report mortality outcomes.

##### Ability of BCR-ABL1 mutation testing to predict response

Of the 16 patients with detected mutations, 13 showed hematologic response to dasatinib, and 8 showed cytogenetic response. None of the 6 patients who were negative for BCR-ABL1 mutations responded to dasatinib. The two patients with the T315I mutation did not respond to treatment.

Because the sample size of this study is very small and there are cells with zero counts in Table 31, the estimates of sensitivity, specificity and likelihood ratios are not robust.

Table 30 BCR-ABL1 and tyrosine kinase inhibitors for CML: characteristics of included studies (third line therapy)

Author, year (Country) | -Sample size, n -Study design -Sampling | Selection criteria | Median age, y [range] (% Men) | Staging distribution, n (%) | Disease status | Median Recent Tumor Load (range) | Prior therapy (n [%]) | -Treatment -Adherence | Median followup, mo [range]
Quintas-Cardama, 2007 (USA)(132) | -23 -Retrospective single-center cohort -Convenience sampling | Failure to imatinib and nilotinib | 58 [19–76] (NR) | Late CP 3 (13); second CP 1 (4); AP 10 (43); BP 9 (39) | Loss of response 15 (65); hematologic resistance 8 (35) | 72% (0.03%–100%) | Imatinib 23 (100); nilotinib 23 (100); IFN 9 (39); allogeneic SCT 2 (9) | -Dasatinib 70 mg/d 13 (57); dasatinib 140 md/d 9 (39); dasatinib 240 mg/d 1 (4) -NR | 4 [1–10]^a^

a Duration of therapy

AP, accelerated phase; BP, blastic phase; CP, chronic phase; IFN, interferon; SCT, stem cell transplantation

Table 31 BCR-ABL1 and tyrosine kinase inhibitors for CML: treatment failure (third line therapy)

Author, year | Outcome (followup) | BCR-ABL1 mutations | Mutation, no response | Mutation, response | No mutation, no response | No mutation, response | Sensitivity (95 %CI) | Specificity (95% CI) | LR+ | LR−
Quintas-Cardama, 2007 | Hematologic response (4 mo) | All identified mutations | 3 | 13 | 6 | 0 | 0.33 (0.07, 0.70) | 0.00 (0.00, 0.25) | 0.36 | 18
Quintas-Cardama, 2007 | Hematologic response (4 mo) | T315I | 2 | 0 | 7 | 13 | 0.22 (0.03, 0.60) | 1.00 (0.75, 1.00) | 7.00 | 0.78
Quintas-Cardama, 2007 | Major cytogenetic response (4 mo) | All identified mutations | 8 | 8 | 6 | 0 | 0.57 (0.29, 0.82) | 0.00 (0.00, 0.37) | 0.60 | 8
Quintas-Cardama, 2007 | Major cytogenetic response (4 mo) | T315I | 2 | 0 | 12 | 8 | 0.14 (0.02, 0.43) | 1.00 (0.63, 1.00) | 3.00 | 0.88

#### Studies of BCR-ABL1 mutation monitoring

Seven studies reported relevant data (Table 32).(150–156) All but one(155) studies were retrospective, and the median sample size was 144 (range, 13 to 319). All studies generally included patients with chronic phase CML treated with standard- or high-dose imatinib as first line TKI therapy. In 3 studies, patients with accelerated phase CML were also included (up to 28 percent of total sample size).(153;154;156)

Five of seven studies assessed routine periodical (typically every 3 to 6 months) monitoring of mutation status.(150–154) Three of them were reported by a same group of investigators in the UK.(150–152) All studies typically performed direct sequencing with or without pyrosequencing in peripheral blood samples collected during routine monitoring of BCR-ABL1 transcript levels (Table 33). Across the five studies the cumulative incidence of emerging mutations ranged from 4 to 23 percent or patients.

The remaining two studies assessed mutations only once during treatment course.(155;156) Only one study specified when the mutation testing was performed (as at 6 months or when imatinib resistance was suspected).(155) In one study mutations emerged at 1 percent frequency.(155)

The seven studies assessed various clinical outcomes suggestive of imatinib resistance in non-uniform followup periods (Table 34). Generally, patients who developed mutations during treatment experienced higher imatinib resistance compared with those with no mutations detected during the followup.

Table 32 BCR-ABL1 and tyrosine kinase inhibitors for CML: characteristics of included studies (monitoring)

Author, year (Country) | -Sample size, n -Study design - Sampling | Selection criteria | Median age, y [range] (% Men) | -Staging, n (%) & -Risk group, n (%) | Response status (median recent BCR-ABL1 level [range], %) | Purpose and timing of mutation testing | Prior therapy | -Treatment -Adherence | Median followup, mo [range]
Routine monitoring
Khorashad, 2008 (UK) | -319 -Retrospective analysis of two prospective trials -Convenience sampling | BCR-ABL+ CML CP treated with imatinib >6 mo followup Sequential samples available | 47 [18–73] (55) | -Early (<6 mo) CP 171 (54); late (≥6 mo) CP 148 (46) -NR | NR | q 6 mo; more often when imatinib resistance suspected | INF 127 (39) | -Imatinib 400 mg/d -NR | 51 [12–90]^a^
De Lavallade, 2008 (UK) | -204 -Retrospective analysis of single-center cohort -“Consecutive” | BCR-ABL+ CML CP treated with imatinib | 46 [18–79] (57) | -CP 204 (100) -Sokal score: low 59 (29); intermediate 86 (42); high 59 (29) | NR | q 6 mo; more often when imatinib resistance suspected | HU | -Imatinib 400 mg/d -54 (26%) discontinued imatinib at a median 16 mo. | 38 [12–85]^b^
Marin, 2009 (UK) | -145 (total samples NR) -Retrospective?; single-center -Consecutive sampling? | Adult BCR-ABL+ CML (CP) Achieved CCR | NR | -CP 145 (100) -NR | CCyR (0.4 [0.3–18]) | q 6 mo; more often when imatinib resistance suspected | No 145 (100) | -Imatinib 400 mg qd adjusted per tolerance and response -NR | 48 [13–95]
Branford, 2003 (Australia) | -144 (353 samples) -Retrospective; multi-center -Convenience sampling | Imatinib treatment At least one sample with nondegraded RNA with measurable level of bcr-abl | NR | -Early CP, 40 (28); Late CP 64 (44); AP 40 (28) [~ENL] -NR | No failure 142 (NR); Imatinib failure 2 (NR) | Available samples only^c^ | No 104 (72); IFN 16 (11); HU 24 (17) | -Imatinib 400 mg qd (CP); Imatinib 600 mg qd (AP) NR | NR
Wei, 2006 (Sweden) | -40 -Retrospective single-center cohort -NR | All CML treated with imatinib | NR [23–80] (53) | -Early (<12 mo) CP 30 (75); 7 late (≥12 mo) CP 7 (18); AP 3 (8) -NR | NR | Before therapy; q 3 mo until BCR-ABL1 transcripts undetectable; q 6 mo thereafter; q 3 mo if imatinib resistance suspected | NR | -Imatinib 400 mg/d (CP); 600 mg/d (AP) NR | NR
Single interim assessment
Hughes, 2008 (Australia) | -103 -Prospective multi-center single arm trial -Unclear | BCR-ABL+ CML CP treated with only HU or anagrelide Diagnosed within the past 8 mo PS 0–2 (ECOG) Adequate renal and hepatic function | 50 [19–76] (64) | -CP 103 (100) -Sokal score: good 26 (25); intermediate 30 (29); poor 28 (27) Hasford score: low 42 (41); Intermediate 21 (20); high 19 (18) | NR | At 6 mo (n=94) or when one met the criteria of mutation screening^d^ (n=7) | HU or anagrelide | -Imatinib 600 mg/d; or 800 mg/d if no CHR at 3mo, no MCyR at 6mo, no CCyR at 9 mo, ≥0.01% BCR-ABL by RQ-PCR at 12 mo -NR | NR
Chu, 2005 (USA) | -13 -Retrospective; single-center -Convenience Sampling | BCR-ABL+ CML CP or AP Achieved CCyR with imatinib Adequate sample available | 54 [37–70] (46) | -Early CP, 7 (54); Late CP, 5 (38); AP, 1 (8) -NR | NR^e^ | 1 available sample per patient^f^ | IFN 6 (46) | -Imatinib 400 mg/d -NR | 15 [2–30]^g^

a Surviving patients only.

b Surviving patients only.

c Samples were originally used for routine BCR-ABL1 transcript level assessment (frequency of sampling not reported). Median 2 samples per patient (range, 1–18) with assessable RNA available for mutation testing.

d Significant rise in RQ-PCR (defined as >2-fold rise).

e 7 out of 8 patients had detectable disease by FISH.

f Bone marrow mononuclear cells or G-CSF mobilized PBSCs were assessed at a median 6 months (range, 3–25) from the start of therapy (reason or timing of sampling not reported).

g No information on followup period for 4 patients.

AP, accelerated phase; BP, blastic phase; BU, busulfan; CML, chronic myeloid leukemia; CCyR, complete cytogenetic response; CHR, complete hematologic response; CyR, cytogenetic response; Cr, creatinine; FISH, fluorescent in situ hybridization; GMCSF, granulocyte-macrophage-colony-stimulating factor; HHT, (semisynthetic) homoharringtonine; HU, hydroxyurea; IFN, interferon-α; L-PAM, melphalan; MCyR, major cytogenetic response; PS, performance status; RQ-PCR, real-time quantitative polymerase chain reaction; SCT, stem cell transplantation; TBil, total bilirubin; 6TG, 6-thioguanine; TopoII, topoisomerase II inhibitor; WHO, World Health Organization.

Table 33 BCR-ABL1 and tyrosine kinase inhibitors for CML: technical specification of mutation testing (monitoring)

Study (first author, year) | Assessed patients, n (% of included patients) | Mutation detection method | Source (Tube) [process and time between collection and RNA extraction, h] | Detection sensitivity (%)
Routine monitoring
Khorashad, 2008 | 319 (100) | DS/PS | PB (NR) [NR] | NR
De Lavallade, 2008 | 204 (100) | DS/PS | PB (NR) [NR] | NR
Marin, 2009 | 145 (100) | DS/PS | PB (EDTA or heparin) [NR] | 30/10
Branford, 2003 | 144 (100) | DS | PB (NR) [processed into Trizol RNA stabilizer and stored at −80°C, NR] | 20
Wei, 2006 | 40 (100) | DS | PB (EDTA) [store at −20 °C] | 20–30
Single interim assessment
Hughes, 2008 | 100 (97)^a^ | DS | NR | NR
Chu, 2005 | 13 (100) | SS | BM 11; PBSC 2 (NR) [NR] | NR

a Some patients who met the criteria of mutation screening may have undergone the mutation test multiple times. Two patients were not tested for no sample and one for no detectable level of BCR-ABL gene.

BM, bone marrow; DS, direct sequencing; EDTA, ethylenediaminetetraacetate; NR, not reported; PB, peripheral blood; PBSC, peripheral blood stem cell; PS, pyrosequencing; RNA, ribo nucleic acid; SS, subcloning and sequencing.

Table 34 BCR-ABL1 and tyrosine kinase inhibitors for CML: reported outcomes by presence of mutations (monitoring)

Author, year | Evaluated patients, n (median followup, mo) | Main outcome assessed | Findings
Routine monitoring
Khorashad, 2008 | 319 (51) | PFS^a^ | Forty-nine (17%) out of 282 patients without mutations detected during treatment developed progression. In contrast, of 37 patients who developed detectable mutations during imatinib therapy, 17 patients (46%) progressed (RR =3.7; P<0.0001). In the final model in multivariate analyses based on a forward stepwise selection, the development of mutations was the only significant independent prognostic factor of progression (RR = 2.3; P=0.01) Subgroup analyses were performed for 250 patients who remained CHR at 2 years (RR=3.0; P=0.004).
De Lavallade, 2008 | 204 (38) | Loss of CCyR, loss of CHR; PFS; and OS | Eleven (5%) patients developed mutations during the followup. The development of mutations during treatment was a significant predictive factor for loss of CCyR (RR=13.4; P<0.001) but not for loss of CHR, PFS, or OS.
Marin, 2009 | 161 (48) | Loss of CCyR in CR^b^ | Of 161 patients with CP who achieved CCyR in first-line treatment with imatinib, 6 (4%) developed mutations, all of who (100%) lost CCyR during the treatment. In those without mutations (n=155), only 12 patients (8%) lost CCyR. The median time from the detection of mutations to loss of CCyR was 17 months (range, 1–39).
Branford, 2003 | 144 (NR) | Imatinib resistance for CP^c^ and for AP^d^ | Twenty-seven (19%) out of 144 patients who had at least one test result developed detectable mutations. Mutations were detected at a median 8 months (range 3–18). None of the patients with early CP (n=40) developed mutations during first-line treatment with imatinib. Fourteen (22%) out of 64 patients with late CP developed mutations during imatinib therapy. Of these, 11 (79%) developed imatinib resistance, whereas only two (4%) experienced imatinib resistance out of 50 patients with late CP without mutations throughout the treatment period. All patients (n=13, 100%) with AP who developed mutations during imatinib therapy developed imatinib resistance, whereas only two (8%) experienced imatinib resistance out of 25 patients with AP without mutations throughout the treatment period.
Wei, 2006 | 40 (NR) | Acquired imatinib resistance^e^ | Out of 9 patients who developed detectable mutations, 7 (78%) experienced an acquired imatinib resistance, whereas only one (3%) out of 31 patients without mutations throughout the followup experienced an acquired imatinib resistance. No patients with detectable mutations during treatment developed primary imatinib resistance (i.e., ≥minimal CyR at 6 mo; MCyR at 12 mo; persistent detectable BCR-ABL gene in blood). Subgroup analyses for early CP patients (n=30) had similar results.
Single interim assessment
Hughes, 2008 | 100 (NR) | Not defined | No specific results were reported on those who met the mutation screening criteria and underwent the test^f^. Only one patient with a mutation out of 94 patients who did not meet the criteria and underwent the test at 6 mo had a significant rise in BCR-ABL during followup.
Chu, 2005 | 13 (15) | Relapse^g^ | Two out of 5 patients with mutations experienced relapse, whereas none developed recurrent leukemia in 8 patients without detectable mutations (all in CCyR at last followup^h^)

a Survival without evidence of AP or BC.

b Druker et al, NEJM 2006.

c Kantarjian et al, NEJM 2002.

d Talpaz et al. Blood 2002.

e Loss of CHR; loss of MCyR/CCyR; and transformation to BC.

f Six (67%) out of 9 patients who lost response had mutations detected. Of these 6 patients, 2 progressed to BC at 3 and 6 months. Another two lost CHR and two additional patients lost CCyR.

g Morphologic or cytogenetic evidence of recurrent leukemia.

h Four out of 5 patients who had rising BCR-ABL gene level in peripheral blood developed mutations at last followup.

AP, accelerated phase; BC, blastic phase; CCyR, complete cytogenetic response; CP, chronic phase; CR, complete response; MCyR, major cytogenetic response; OS, overall survival; PFS, progression free survival;

## 3.4 Discussion

In our systematic review of the literature, presence of any BCR-ABL1 mutation does not appear to predict differential response to treatment in CML patients treated with imatinib-, dasatinib-, or nilotinib-based regimens. There is consistent evidence that presence of the relatively rare T315I mutation can predict TKI treatment failure, mainly in terms of hematologic and cytogenetic response. In contrast, there is no evidence that that presence of any BCR-ABL1 mutation can differentiate response to TKI therapies. Further, the majority of evidence pertains to the short term surrogate outcomes of hematologic, cytogenetic or molecular response. Data on overall or progression-free survival are sparse. Finally, most evidence is on second line TKI treatments, especially dasatinib and nilotinib, and originates from a small number of referral cancer centers where those agents were first-tested before becoming more widely available.

Less than 9 percent of patients in any single included study had the relatively rare T315I mutation. Across all studies all, or almost all, patients with the T315I mutation have adverse response to treatment. This observation is in accordance with the prevailing knowledge in the field, and with the literature review performed for the updated European Leukemia Net recommendations, which suggests that patients with the T315I mutation consider allogeneic stem cell transplantation.(118) The ability of T315I mutation to predict TKI treatment failure seems to be similar across all studies, and thus applicable to all examined TKI-based treatments. However, most included studies pertain to second line TKI treatment with dasatinib, while the corresponding epidemiologic data on imatinib and nilotinib are sparse. Nevertheless, the updated European Leukemia Net recommendations state that mutation testing should be performed in all patients with suboptimal response or failure in first-line imatinib therapy before changing treatment, and that patients with the T315I mutation in particular should be considered for allogeneic stem cell transplantation.(118)

There is an apparent discrepancy between our findings on any BCR-ABL1 mutation testing, and testing specifically for the T315I mutation. This can be explained by a dilution of the effect of the T315I mutation when other, more common mutations that do not confer resistance to treatment (or confer less resistance) are taken into account. This result is emblematic of the complexity of the topic: different mutations may confer different varying degrees of resistance to each of the three drugs. Exploring such relationships with systematic reviews of published aggregate data is extremely challenging. Other approaches, including collaborative registries of CML patients are much better suited to address such questions.^a^ Collaborative international registries offer the advantages of standardized disease stage definitions, outcomes, treatments and assessment of mutations; allow the opportunity to analyze large numbers of patients, increasing the statistical power for analyzing associations of rare mutations; and may yield results that are widely applicable. After all, as described in the legend of Figure 12, most included CML studies originate from a limited number of world-leading referral centers.

a See for example http://www.eutos.org/content/registry/ (last accessed 12/07/2009).

We documented extensive between-study heterogeneity in treatments, the identified mutations, and the disease stages of the enrolled patients. This does not appear to translate to differences in the predictive ability of included studies, either for any BCR-ABL1 mutation testing or specifically for T315I mutation testing. Although we did not perform statistical tests for heterogeneity, all studies on any BCR-ABL1 mutation testing fall into areas of poor prognostic performance, and all studies on T315I are consistent between them. This suggests that even if there is statistical heterogeneity, there is little clinically relevant information we can obtain from exploring it.

In conclusion, the results of our systematic review are in accordance with the prevailing knowledge in the field. Analyses of individual patient data rather than systematic reviews of aggregate data are better suited for exploring the complex relationships between various mutational patterns and conferred resistance to different TKIs. A pragmatic approach towards this goal is to support high quality registries of CML patients with detailed information on clinical and molecular variables, and well characterized outcomes.

### Key Question 2 What patient- and disease-related factors affect the test results, their interpretation or their predictive response to therapy?

None of the included studies performed analyses for interaction between the aforementioned factors and BCR-ABL1 mutation testing to predict response to therapy.

### Key Question 3 How does the gene testing impact the therapeutic choice?

No study explicitly reported details on changes in treatment plans before and after testing.

### Key Question 4 What are the benefits and harms or adverse effects for patients when managed with gene testing?

No study explicitly reported evidence on benefits or harms beyond what is covered in Key Question 1.