# Section 2: Variations in KRAS and response to cetuximab and panitumumab in colorectal cancer

## 2.1 Background

The epidermal growth factor receptor (EGFR, also known as HER1 or c-erbB-1) is a transmembrane growth factor receptor with tyrosine kinase activity. EGFR is a member of the human epidermal growth factor receptor (HER) family which includes 3 more members: HER2 (HER-2/c-erbB-2/NEU), HER3 (HER-3/c-erbB-3), and HER4 (HER-4/c-erbB-4). EGFR is activated by the binding of ligands such as epidermal growth factor (EGF), transforming growth factor-α (TGF-α), or amphiregulin. Ligand binding induces a series of biochemical events^a^ that activate intrinsic tyrosine kinase activity of the intracellular domains of the receptor complex. Subsequently, the now activated kinase domain of the receptor phosphorylates intracellular substrates, resulting in the activation of several downstream signaling pathways.(49) The most important are the RAS-RAF- mitogen-activated protein kinase (MAPK) pathway, the phosphatidylinositol 3-kinase (PI3K) -Akt pathway and the phospholipase Cγ pathway.(50) EGFR-mediated signaling has been implicated in several cellular processes including cell proliferation, resistance to apoptosis, enhanced cell motility and neoangiogenesis. These processes are central to the pathogenesis of a variety of epithelial cancers, including lung, breast and colorectal cancer.

a These include receptor autophosphorylation and receptor dimerization (either homodimerization or heterodimerization involving other members of the ERBB family).

The central role of EGFR in cancer pathogenenesis, along with evidence indicating that EGFR expression in tumor tissues may predict adverse outcomes, has motivated an extensive translational effort to develop therapies specifically targeting this receptor. Colorectal cancer, were overexpression of EGFR occurs frequently, has long been considered a good candidate disease for implementing EGFR-targeted therapies such as antibodies targeting the EGFR protein.

Monoclonal anti-EGFR antibodies were first produced in the 1990s.(51–53) These antibodies target the extracellular domain of EGFR and are believed to exert their effects through a variety of mechanisms, including blocking EGFR activation, causing increased EGFR internalization and inducing cell-mediated immune cell cytotoxicity.(49) Currently, two monoclonal anti-EGFR antibodies are licensed in the USA for the treatment of colorectal cancer: cetuximab^b^ and panitumumab.^c^ Cetuximab is a chimeric mouse-human monoclonal antibody, whereas panitumumab is a fully human monoclonal antibody.(54) Both agents have been evaluated for the treatment of metastatic colorectal cancer, both as monotherapy and in combination with cytotoxic chemotherapy. Although initial studies used EGFR expression as a requirement for enrollment, it appears that both cetuximab and panitumumab are active, irrespective of EGFR expression.(55–57) Furthermore, their anti-tumor activity appears to be similar (although direct randomized comparisons have not been reported) but panitumumab has lower immunogenicity and causes fewer infusion reactions (because it is fully human).(54)

b ER-K0034, Erbitux, Merck-Serono KgaA, Darmstadt, Germany; ImClone Systems Inc, New York, NY.

c ABX-EGF, Vectibix; Amgen Inc, Thousand Oaks, CA.

Although both anti-EGFR antibodies have demonstrated anti-tumor activity in colorectal cancer patients in a variety of treatment settings, response rates have been relatively low (around 10% for chemotherapy pre-treated patients) and the majority of patients experience disease progression while under treatment.(58–61) Low response rates and high rates of progression have motivated a number of translational investigations attempting to identify the molecular basis of resistance to anti-EGFR antibodies. One hypothesis that has been explored in a large number of studies is that genetic aberrations of the genes encoding downstream effectors of EGFR-mediated signaling could be related to resistance to anti-EGFR antibody therapy.(54)

Kirsten-RAS (KRAS), a member of the rat sarcoma virus (ras) gene family of oncogenes, is a central signaling “node” that integrates several signaling cascades controlling gene transcription, including many EGFR-mediated pathways.(62;63) KRAS is frequently mutated in epithelial cancers including colorectal cancer, where the mutational frequency is estimated to be approximately 35–45 percent. Mutations occur in certain “mutational hotspots”, corresponding to codons 12 and 13 of the KRAS protein. Although mutations affecting other protein residues (including codon 61) have been reported, they represent a minority of reported mutations.(64) KRAS mutations result in continuous activation of the downstream RAS-RAF-MAPK or PI3K pathways, regardless of whether the EGFR is activated or pharmacologically blocked (constitutive activation).(3;54) Such activation increases the transcription of oncogenes implicated in cancer progression and metastasis.

Given the central role of KRAS in integrating EGFR-mediated signaling, and the ability of KRAS mutations to induce EGFR-independent cancer growth, it was hypothesized that the presence of KRAS mutations could abrogate the effects of anti-EGFR antibodies and precludes any beneficial effects of antibody therapy. In this framework, KRAS mutations may predict resistance (lack of response) to anti-EGFR antibodies. Here we report a systematic review of the available evidence on the ability if KRAS testing to predict response to treatment with cetuximab or panitumumab in colorectal cancer patients.

## 2.2 Methods

The reader is referred to the Generic Methods section for a description of methods common to all three topics examined in this review. Herein we describe the topic-specific Key Questions, as well as additional topic-specific methods.

### Key questions

1. Does KRAS testing predict response to cetuximab or panitumumab therapy?
2. What patient- and disease-related factors affect the test results, their interpretation or their predictive response to therapy?
3. How does the gene testing impact the therapeutic choice?
4. What are the benefits and harms or adverse effects for patients when managed with gene testing?

The interpretation of the Key Questions is provided in the Generic Methods section.

### Literature search strategy

The actual search strategy is listed in Appendix A. Briefly, we searched OVID MEDLINE, from inception to March week 3, 2010, using combinations of the terms “cetuximab”, “panitumumab”, “colorectal cancer” and their synonyms. We did not use terms for KRAS to increase the sensitivity of the searches.

### Eligibility criteria

Eligible were studies that fulfilled the generic eligibility criteria listed in the Generic Methods section. Eligible studies reported on human subjects with colon or rectal cancer and presented information on clinical outcomes (mortality and/or overall survival; disease recurrence and/or progression free survival or time-to-progression or response rates) stratified by KRAS mutational status.

We considered all study designs (prospective and retrospective), treatment settings (first line versus second line or higher), treatment strategies (anti-EGFR antibody monotherapy versus combination with cytotoxic chemotherapy).

### Extracted data

See the Generic Methods Section for commonly extracted items across the three cancer topics. Data specifically collected for studies pertinent to the current topic include tumor characteristics (including tumor anatomic location and stage), information regarding the number and types of prior chemotherapy regimens received, number of patients participating in the study and included in genotyping analyses, KRAS mutation testing methodology and results of KRAS genotyping, outcomes assessed and outcomes stratified by KRAS mutation status.

### Outcomes

As described in the Generic Methods section three categories of outcomes were analyzed: mortality (all-cause or from colorectal cancer); progression, or the composite outcome of death or progression; and treatment failure, defined as absence of tumor response by imaging. We accepted each study’s definition of colorectal cancer-specific mortality, cancer progression or treatment failure.

### Synthesis

#### Mortality and disease progression

For time-to-event outcomes (overall and progression-free survival or time to progression) we did not perform any quantitative synthesis, because most studies did not report sufficient statistics necessary for meta-analysis. Instead, we summarize studies qualitatively. We list odds ratios and 95% confidence intervals (for analyses of cumulated events) or hazard ratios and 95% confidence intervals (for time-to-event analyses).

#### Treatment failure by imaging

For this outcome we performed two different sets of analyses (see Generic Methods). The first set evaluated the test performance of KRAS mutation testing for predicting treatment failure at a specific time point. The second set of analyses evaluated the strength of association between the presence of KRAS mutations and treatment failure.

To assess test performance we calculated the sensitivity, specificity, LR+ and LR- of KRAS testing to predict adverse outcomes as described in the Generic Methods

Because treatment failure was reported by the majority of studies, and reporting was relatively uniform, we performed meta-analysis to calculate summary estimates of the association of KRAS mutations with “lack of response” as well as their predictive accuracy for the same outcome. We took care not to include in the meta-analysis studies with overlapping populations, to avoid duplication of information. When several overlapping publications were identified, we selected the one with the largest number of patients. The methods for quantitative synthesis are presented in the Generic Methods section.

## 2.3 Results

### Literature flow

Our searches returned 1949 citations. After screening of titles and abstracts 164 were retrieved and reviewed in full text. Forty-six publications were finally eligible.(58;59;61;65–92) Appendices B and C show the list of included and excluded citations, respectively. Figure 4 summarizes the literature flow.

Figure 4 KRAS and anti-EGFR antibodies for colorectal cancer: literature flow

Figure 4. KRAS and anti-EGFR antibodies for colorectal cancer: literature flow. (page 33) Figure 4 is a type of diagram that depicts the literature search, and literature scan. The electronic literature search (MEDLINE) yielded 1779 citations, of which 119 papers were retrieved in full text. 29 and 2 were considered for reviews of studies of metastatic colorectal cancer and of neoadjucant studies, respectively, of which 31 were included. 88 were excluded for the following reasons: genotyping for KRAS mutations not performed (n=72), case series with fewer than 10 patients (n=1), no clinical outcomes of interest reported (n=3), irrelevant studies (n=10), relevant data not extractable (n=2), or secondary analysis of microarray data (n=1). Irrelevant studies include those with no drugs of interest, non clinical studies, and narrative reviews. Perusal of references of the 31 selected papers did not find any further eligible papers.

### Characteristics of included studies

Tables 8 and 9 summarize the characteristics of the 47 eligible studies.(58;59;61;65–108)

#### Patients

Briefly, two studies were conducted in the neo-adjuvant setting,(65;70) eight studies pertained to patients who received anti-EGFR antibodies as part of the first regimen received for metastatic disease,(58;61;91–96) and all other studies included patients with metastatic disease who had previously been treated with cytotoxic chemotherapy. In studies conducted in the metastatic setting, the majority of patients had received prior treatment with at least one chemotherapy regimen; both the number and types of treatment regimens administered varied across studies. Mean or median participant age was 65 or older in 6 of the 41 studies that reported relevant information, and 60 or older in 32 of the 40 studies that reported relevant information. As shown in Table 8 and Table 9, the distribution of anatomic tumor location (colon versus rectum) varied across studies and was often not reported. In terms of racial composition, the information was not reported in most studies; no study was exclusively conducted in the USA. Thirty four studies were conducted in Europe, 4 studies pertained to East Asian populations and 8 studies were conducted in a multinational setting (all 8 were prospective multicenter studies) and 1 study reported on a combined USA and European group of patients.

#### Treatments

All but two studies pertained to patients who received anti-EGFR antibodies for metastatic colorectal cancer. Two studies pertained to the use of cetuximab in combination with cytotoxic chemotherapy and radiotherapy for the treatment of rectal cancer before surgery (neo-adjuvant study) and their results will be discussed separately.(65;70) Thirty five studies reported exclusively on patients receiving cetuximab (as monotherapy in 4 studies; in combination with cytotoxic chemotherapy in 23 studies; both as monotherapy and in combination in 8 studies), 4 on patients receiving panitumumab (in 3 studies as monotherapy and in 1 study as part of combination therapy) and 6 on mixed patient populations receiving both drugs (panitumumab as monotherapy and cetuximab both as monotherapy and in combination in all cases). Anti-EGFR antibody dosing was commonly not mentioned, particularly in reports of retrospective studies. Given that many of the patients in these studies were participants in larger, multicenter clinical trials, drug dosing in the studies included in this report can be expected to be similar to that employed in the prospective trials. Treatment strategies are summarized in Table 7.

Table 7 KRAS and anti-EGFR antibodies for colorectal cancer: treatment strategies employed in the eligible studies

Treatment strategy | Monotherapy | Combination therapy | Both | TOTAL
Cetuximab | 4 | 23 | 8 | 35
Panitumumab | 3 | 1 | 0 | 4
Both | 0 | 0 | 6^a^ | 6
TOTAL | 7 | 24 | 14 | 45

a In all 6 studies cetuximab was administered both as monotherapy and in combination with cytotoxic chemotherapy, whereas panitumumab was administered as monotherapy.

This table presents the treatment strategies employed in the 45 studies reporting on patients with metastatic colorectal cancer. The studies by Debucquoy 2009 and Bengala 2009 are not included in this table because of the different treatment strategies usually employed in the neoadjuvant setting.

#### Design

Only 3 studies (including both neoadjuvant studies) explicitly stated that sample collection and subgroup analysis by KRAS testing was a pre-specified aim of the study.(59;65;70) In the remaining 44, outcome assessment was frequently described as prospective, while KRAS testing was performed on archival samples, indicating that the major driver of inclusion into each study was sample availability. The majority of studies (41 studies) assessed the ability of KRAS testing to predict outcomes only in patients who received anti-EGFR antibodies. This design essentially assumes that KRAS testing has no predictive ability for colorectal cancer outcomes in patients who did not receive anti-EGFR antibodies.^b^ Seven studies presented analyses based on RCTs.(58;59;61;77;91;93;95) These RCT-based analyses included patients who received cetuximab or panitumumab (alone or in combination with chemotherapy) (“antibody” arm), as well as patients who received other treatments (chemotherapy alone or best supportive care, “comparator” arm), and provide an opportunity to examine pharmacogenetic effects of KRAS genotyping by testing the interaction of genotypes and treatments.^c^

b As discussed regarding the predictive effect of CYP2D6 polymorphisms for response to tamoxifen, if KRAS status predicted colorectal cancer outcome irrespective of treatment, studies that evaluate only anti-EGFR treated patients would still find an association between KRAS status and patient outcomes; however the association would not be specific to tamoxifen treated people, and therefore would not be evidence for a pharmacogenetic interaction.

c Testing for interaction answers whether an observed association between KRAS status and patient outcomes is specific to those who received anti-EGFR antibodies, or is independent of treatment. This analysis would not invoke the assumption outlined in the previous footnote.

Both cetuximab and panitumumab have been investigated by an extensive network of phase II and phase III clinical trials. Many of the centers participating in these trials have analyzed tissue samples from their patient cohorts for KRAS mutations and have presented a number of post hoc analyses, often including patients treated outside the clinical trials. When the clinical trial results are published, analyses stratified by KRAS status are often presented. In addition, several “pooled” analyses of such analyses have been published, resulting in substantial overlap in the published reports. Using the conventions described in the Generic Methods Section we identified studies reporting on (partially or completely) overlapping patient populations (Figure 5).

Sample sizes in the 45 studies conducted in the metastatic setting ranged between 12 and 440 patients^d^. The seven analyses based on RCTs included 1588 patients treated with anti-EGFR antibodies and 1481 patients treated in the “comparator arms”, for a total of 3069 patients assessed for KRAS mutations^e^. In the metastatic setting, median follow-up duration ranged from 9 to 26 months, and was commonly not reported.^f^

d Numbers refer to individuals assessed for KRAS mutations and treated with anti-EGFR antibodies.

e Numbers refer to patients assessed for KRAS mutations. In the study by Folprecht 2010 both arms received cetuximab.

f Numbers do not include studies where duration of follow-up since the original diagnosis of metastatic disease was reported.

Figure 5 KRAS and anti-EGFR antibodies for colorectal cancer: publications that enrolled at least partially overlapping populations

Overlap between included studies. Each publication is represented by an ellipse. Studies reporting on partially or overlapping cohorts of patients are presented as a group of ellipses linked amongst themselves with lines. Refer to the Generic Methods Section for a description of how overlap was assessed.

*Studies selected for meta-analysis to avoid duplication of information (see later in this section).

Figure 5. "KRAS and anti-EGFR antibodies for colorectal cancer: publications that enrolled at least partially overlapping populations. (page 36) Meta-analysis for the ability of KRAS mutations to predict response to anti-EGFR antibodies. Each study is represented by a gray circle with size proportional to the study size. The summary point is represented by a black square and the dashed line represents the 95% confidence region of the summary estimate. The majority of studies had high specificities but relatively low sensitivities. The summary estimate also indicated a specificity higher than 0.9 but a sensitivity of approximately 50%."

Table 8 KRAS and anti-EGFR antibodies for colorectal cancer: characteristics of included studies (first line therapy)

Author, year (Country) | -Sample size^a^, n -Study design -Sampling | Selection criteria | Median age, y [range] (% Men) | -Cancer site -Staging [criteria] distribution, n (%) | Patients in first line therapy (%) | Prior chemotherapy | -Treatment regimen -Adherence | Median followup, mo [range]
Randomized controlled trials
Bokemeyer, 2009(58)^b^ (Multinational) | -233 -Retrospective analysis based on phase II RCT -Convenience sampling | Adult patients with Histologically-confirmed EGFR-expressing CRC with at least one radiologically measurable lesion and PS≤2. | Cetuximab arm: 59 [24–82] (50) Not receiving cetuximab: 60 [30–82] (55) | -Colon 127 (55); rectum 105 (45); colon + rectum 1 (0.4) -Metastatic 233 (100) | 86^c^ | NA | -2 arm study: arm A: FOLFOX-4, arm B: FOLFOX-4+cetuximab until progressive ddisease or toxicity -In the cetuximab group 84% of patents had RDI≥80% | NR
Hecht, 2009(93) (Multinational) | -865^e^ (from 1053) -Prospective analysis based on a phase III RCT^f^ -Patients were assigned to two cohorts (oxaliplatin-based and irinotecan-based chemotherapy) based on physician preference. Both cohorts received bevacizumab and patients were randomized into panitumumab vs. control arms -Convenience sampling | Pathologically diagnosed metastatic CRC patients with no prior chemotherapy of biologic therapy for metastatic disease. Measurable disease and ECOG PS ≤0. | Oxaliplatin, bevacizumab, panitumumab: 61 [28–88] (56) Oxaliplatin, bevacizumab: 62 (22–89) [58] Irinotecan, bevacizumab, panitumumab: 60 [35–84] (49) Irinotecan, bevacizumab: 59 [23–80] (62) | -Colorectal 1053 (100) -Metastatic 1053 (100) | 100 (for metastatic disease) | 231 patients (37%) had received prior adjuvant chemotherapy | -97% received panitumumab 6 mg/kg as their first dose; 95% received bevacizumab 5 mg/kg as their first dose - the proportion of patients receiving a RDI ≥85% of bevacizumab and each chemotherapy agent in both chemotherapy cohorts was lower in the panitumumab arms (33% for panitumumab vs. 42% for control for Ox-CT; 34% for panitumumab v 44% for control for Iri-CT) | Oxaliplatin, bevacizumab: 12 [0–26] Irinotecan, bevacizumab: 9 [0.3–24]
Tol, 2009 (Netherlands)(91) | -736^g^ -Prospective analysis^h^ of RCT between CB and CBC -Convenience sampling | >18 y, WHO PS 0–1 Measurable colon or rectal cancer with metastatic disease No indication of curative surgery No previous systemic chemotherapy or neoadjuvant chemotherapy <6 mo^i^ | 62 [27–83] (60) | -Colon 336 (46); Rectum 202 (27); Rectosigmoid 198 (27) -Metastatic 736 (100) | 100 | None | -Capecitabine 2000 mg/m^2^ d1-14 + oxaliplatin 130 mg/m^2^ d1 + bevacizumab 7.5 mg/kg d1; q 3 wk. (CB) vs. the same regimen plus cetuximab 250 mg/m^2^ d1; q 3 wk^j^ (CBC) -NR | 23
Van Cutsem, 2009(61)^k^ (Multinational) | -540 -Retrospective analysis based on a phase III RCT -Convenience sampling | Adult patients with colorectal adenocarcinoma and unresectable metastatic disease | Cetuximab arm: 61 [22–79] (62) Not receiving cetuximab: 62 [22–79] (53) | -Colon, 317 (59); rectum, 217 (40); other, 6 (1) -Metastatic 540 (100) | 84^l^ | NR | -FOLFIRI arm: irinotecan 180 mg/m^2^ BSA; leucovorin or L-leucovorin 400 or 200 mg, respectively/m^2^; 5-FU 400 mg/m^2^ followed by continuous infusion for 46 hours of 2400 mg/m^2^ Cetuximab+FOLFIRI arm: cetuximab 400 mg/m^2^, followed by weekly 250 mg/m^2^ -NR | NR
Folprecht, 2010(95) (Germany + Austria) | -111 -Retrospective analysis based on a phase II RCT -Patients were randomly assigned to two alternative chemotherapy regimens (FOLFOX or FOLFIRI), both in combination with cetuximab -Convenience sampling (based on tissue availability) | -Patients with unresectable, Histologically confirmed metastatic colorectal cancer. Only patients with liver metastases and no other evidence of metastatic disease were enrolled. -Patients having received previous chemotherapy (except adjuvant chemotherapy ≥6 months before enrollment) were excluded | FOLFOX arm: 65 [57–71]^m^ (64) FOLFIRI arm: 62 [56–68] (64) | -Colorectal cancer with liver metastases 111 (100) -Metastatic disease 111 (100) | 100 | -18 (16%) of patients had received prior adjuvant chemotherapy. No patient had received chemotherapy in the metastatic setting. | -Cetuximab (400 mg/m2 on day 1, followed by 250 mg/m2 weekly thereafter every 2 weeks, followed by either FOLFOX6 (day 1, oxaliplatin 100 mg/m2, folinic acid 400 mg/m2, and fluorouracil 400 mg/m2 intravenous bolus, then 2400 mg/m2 over 46 h continuous infusion, or FOLFIRI (day 1, irinotecan 180 mg/m2, fluorouracil and folinic acid as described for the FOLFOX group) | NR
Single arm studies
Bengala, 2009(65) (Italy) | -40 -“Correlative study” based on a phase II prospective single arm clinical trial of cetuximab + chemoradiotherapy for rectal cancer -From all 40 patients (representative) | -Histologically confirmed locally advanced rectal cancer, stage T3-T4; N0-N1 rectal carcinoma with no evidence of distant metastasis | 61 [28–77] (85) | -Rectum (100) -Locally advanced rectal cancer 40 (100) | 100 | NA | -Cetuximab 400 mg/m^2^ loading dose for three, then 250 mg/m^2^ weekly, followed by cetuximab 250 mg/m^2^ weekly plus 5-FU (225 mg/m^2^/day IV 7 days a week for 5 weeks) + radiotherapy [15–18 MV photon beams, at 1.8–2 Gy/fraction up to 50–50, 4 Gy in 25–28 daily fractions for 5 days a week] -Median number of cetuximab: 8; 70% of the patients completed the planned doses; 38 patients underwent radical surgery (one refused surgery and the other had disease progression under therapy and was operated on^n^) | NR
Debucquoy, 2009(70) (Belgium) | -41 Prospective phase I/II clinical trial -From all 41 patients (representative) | -Histologically proven rectal adenocarcinoma, stage T3-T4 and/or N1-N2, ECOC performance status ≤2 and acceptable liver, renal and hematological parameters^o^ | NR | -Rectum (100) -Advanced rectal cancer 41 (100) | 100 | NA | -Capecitabine [650 mg/m2 twice daily (4 patients), or 850mg/m2 twice daily (37 patients)] + cetuximab (loading dose 400 mg/m2, followed by 250mg/m2 weekly) + radiotherapy (1.8 Gy/day for 25 days) -NR | 32 [5–46]
Yen, 2009(92) (Taiwan) | -76 -Retrospective analysis of a cohort -Convenience sampling | -Metastatic colorectal cancer treated with FOLOX or FOLFIRI+cetuximab where tumor and peripheral blood samples available, measurable lesions by CT | 64 [39–83] (58) | -Colon 55 (72) Rectum 21 (28) -Metastatic disease 76 (100) | NR | NR | -Cetuximab + FOLFOX, 54 (71) ; cetuximab + FOLFIRI, 22 (29) | 20 [4–34]
Tabernero, 2010(94) (Spain)^p^ | -62 -Secondary analysis based on a prospective multicenter cohort study of cetuximab monotherapy followed by sequential assignment to different cetuximab-FOLFIRI combinations -Convenience sampling (based on tissue availability) | -Adults with histologically confirmed, EGFR-expression positive metastatic colorectal cancer. | 65 [39–80] (63) | -Colon 36 (58); rectum 23 (37); colon/rectum 3 (5) -Metastatic 62 (100) | 100 | -11 patients (18%) had received prior adjuvant or neoadjuvant chemotherapy | -Cetuximab monotherapy 6 wk, followed by cetuximab plus FOLFIRI until disease progression. -Patients in the control arm received cetuximab as a 400 mg/m^2^ initial dose then 250 mg/m^2^ per wk; patients in the dose-escalation arms received 400 to 700 mg/m^2^ every second wk. -In the monotherapy phase, 97% of patients achieved RDI≥90% for cetuximab. In the combination phase, 70% achieved an RDI≥90% | NR
Yen, 2010(96) (Taiwan) | -95 -Retrospective cohort study -Convenience sampling | -Adults with histologically confirmed metastatic colorectal cancer -Tumor DNA availability -Life expectancy >3 months, prior cytotoxic or radiation therapy completed at least 4 weeks prior to enrollment | 66 [39–86] (58) | -Colon 71 (75); rectum 24 (25) | NR | NR | -Cetuximab + FOLFOX 74 (78); cetuximab + FOLFIRI 21 (22) | NR

a Number of included patients typically assessed for baseline clinical characteristics, not necessarily the same as the number assessed for KRAS mutations.

b Data abstracted for the subgroup of patients assessed for KRAS mutations.

c 33 patients (of whom 14 were in the cetuximab+FOLFOX arm) had received adjuvant chemotherapy.

d Initial dose 400 mg/m^2^ over 2 hours followed by a weekly dose of 250 mg/m^2^ over one hour.

e Data abstracted for the subgroup of patients assessed for KRAS mutations.

f Availability for tissue was an inclusion criterion in the study.

g The number of patients randomized and assessed for baseline characteristics. 368 were treated with cetuximab. Baseline characteristics are for the 736 subjects.

h It is unclear whether the assessment of KRAS mutations was also prospectively planned.

i Those with sensory neuropathy, symptomatic CNS metastasis, bleeding diathesis, coagulation disorders, significant cardiovascular disease, previous other cancers <5 y excluding squamous or basal carcinoma of the skin or carcinoma in-situ of the cervix were excluded.

j 400 mg/m^2^ for the first course.

k Data abstracted for the subgroup of patients that underwent KRAS mutational testing.

l 16% of the patients had received adjuvant chemotherapy. Patients were eligible if no prior chemotherapy for metastatic disease had been administered.

m Age [interquartile range].

n This patient was considered a treatment failure in the original report.

o Eligibility criteria were abstracted from Machiels et al., Ann Oncol, 2007.

p Some patient characteristics were extracted from Tabernero et al., Ann Oncol, 2009.

BSA, body surface area; BSC, best-supportive care; CAPOX, capecitabine + oxaliplatin; CB, capecitabine, oxaliplatin, bevacizumab; CBC, capecitabine, oxaliplatin, bevacizumab, cetuximab; CNS, central nervous system; CPT-11, irinotecan, EGFR, epidermal growth factor receptor; FISH, fluorescence in situ hybridization; FOLFIRI, irinotecan, fluorouracil, and folinic acid; FOLFOX, oxaliplatin, fluorouracil, and folinic acid; IAH, intra-artery hepatic infusion; IHC, immunohistochemistry; LV5FU2, leucovorin, 5-fluorouracil; NA, not applicable; NR, not reported; PS, performance status; RCT, randomized controlled trial; RDI, relative dose intensity; WHO, World Health Organization.

Table 9 KRAS and anti-EGFR antibodies for colorectal cancer: characteristics of included studies (salvage therapy)

Author, year (Country) | -Sample size^a^, n -Study design -Sampling | Selection criteria | Median age, y [range] (% Men) | -Cancer site -Staging [criteria] distribution, n (%) | % Patient in First- line Therapy | Prior chemotherapy | -Treatment -Regimen Adherence | Median followup, mo [range]
Randomized controlled trials
Amado, 2008(59) (Belgium, Italy) | -427 -Pre-specified subgroup analysis based on a randomized phase III RCT (panitumumab + BSC versus BSC alone) -Prospective selection of patients | -Patients with EGFR expressing metastatic colorectal cancer progressing after fluoropyrimidine therapy, having previously received oxaliplatin and irinotecan | Panitumumab arm: 62 [27–79] (56) among KRAS positive and 63 [29–82] (67) among KRAS negative BSC arm: 62 [27–83] (64) among KRAS positive and 63 [32–81] (64) among KRAS negative | -Colon 286 (67) Rectal 141 (33) -Metastatic 427 (100) | 0 | -Fluoropyrimidine-based, oxaliplatin, irinotecan -133 patients in the panitumumab arm and 137 in the BSC arm had received 2 prior lines of chemotherapy; 64 patients in the panitumumab arm and 73 in the BSC arm had received 3 prior lines of chemotherapy | -2 arm study: Arm A: panitumumab 6 mg/kg every 2 weeks + BSC versus; Arm B: BSC alone -Mean number of panitumumab infusions was 10 (median=8) in KRAS negative patients and 4.9 (median=4) in KRAS positive patients | NR
Karapetis, 2008(77) (Multinational) | -394 -Prospective analysis^b^ of RCT -Convenience sampling | -Advanced CRC, failed all prior chemo, no prior treatment with EGFR inhibitor. | 63 [29–88] (64) | -Colon 332 (58); rectum 133 (23); both sites 107 (19) -NR (all subjects had “advanced CRC”) | 0 | -Thymidylate synthase inhibitor 394 (100); irinotecan 380 (96); oxaliplatin 385 (98); radiotherapy 127 (32) | -Cetuximab loading dose 400mg/m^2^, followed by 250mg/m^2^ weekly | NR
Single arm studies
Moroni, 2005(85) (Italy) | -31 -Retrospective cohort study of patient enrolled in cetuximab or panitumumab clinical trials -Convenience sampling | -EGFR expressing metastatic colorectal cancer | 65 [41–85] (71) | -NR -Metastatic disease 31 (100) | 35^c^ | -Patients had received a variety of regimens for metastatic disease. -FOLFOX 18 (58); FOLFIRI 16 (52); any irinotecan-based regimen 20 (65); other 9 (29) | -Panitumumab monotherapy, 10 (32); Cetuximab monotherapy, 12 (39); Cetuximab + irinotecan -based chemotherapy, 9 (29) -NR | NR
Lievre, 2006(80) (France) | -30 -Retrospective multi-center cohort -Convenience sampling | -Metastatic colorectal adenocarcinoma -Underwent a surgical resection of primary tumor -Received cetuximab | 62 [41–78] (63) | NR | 10 | -FOLFIRI 22 (73); FOLFOX 20 (67); LV5FU2 11 (37); IAH 6 (20) | -Cetuximab alone 1 (3); cetuximab + irinotecan 25 (83); cetuximab + FOLFIRI 4 (13) -NR | NR
Benvenuti, 2007(66) (Italy) | -48 -Retrospective single-center cohort (patients were enrolled in clinical trials evaluating panitumumab treatment) -Convenience sampling | -EGFR-expressing metastatic colorectal cancer | 61 [39–84] (63) | -NR -Metastatic disease 48 (100) | 23^d^ | -Number of prior regimens^e^ 2–3, 58 (45); 4–5, 60 (46); 6–8, 12 (9) -Patients received cetuximab+irinotecan therapy when disease progression had been observed during or within 3 months of receiving an irinotecan-based regimen | -Cetuximab alone 12 (25); Panitumumab alone 25 (52); Cetuximab + irinotecan-based chemotherapy 11 (23) -NR | NR
Di Fiore, 2007(72) (France) | -59 -Multi-center retrospective cohort -Convenience sampling | -Metastatic colorectal cancer -Treated with cetuximab (2004–2005) -Tumor DNA available | NR | NR | 0 | ≥1 regimen | -Cetuximab + irinotecan or oxaliplatin -NR | NR
Frattini, 2007(73) (Switzerland) | -27 -Retrospective single center cohort (18 of the patients participated in clinical trials of cetuximab) -Unclear | -Histologically confirmed metastatic colorectal cancer -EGFR expression by the primary tumor [IHC] | 67 [29–84] (67) | -Colon (19) + rectal (8) -Metastatic disease 27 (100) | 15 | -FOLFOX (11), CPT-11 (9); FOLFIRI (8), CAPOX (4), other (7) | -Cetuximab + irinotecan-based, 23 (85); cetuximab + CAPOX-based 4 (15) -NR | NR
Khambata-Ford, 2007(78) (Multinational) | -110 -Prospective multi-center cohort^f^ -Unclear | -Metastatic CRC, at least one prior chemo regimen or refused treatment, pretreatment core tumor biopsy of metastatic lesion available | 61 [25–89] (50) | NR | 0 | NR | -Cetuximab loading dose 400mg/m^2^, followed by 250mg/m^2^ weekly, eligible for dose escalation q 3 wk up to max of 400mg/m^2^ -NR | NR
Cappuzzo, 2008(68) (Italy) | -85 -Retrospective cohort -Convenience sampling | -Chemo-refractory metastatic colorectal cancer -Received cetuximab-based therapy -Previously evaluated for EFGR by FISH | 63 [NR] (64) | -Colon 65 (77); Rectum 20 (24) -NR | 0 | -Irinotecan 71 (84) and/or oxaliplatin 72 (85) | -Irinotecan 180 mg/m^2^ q2wk + cetuximab 250 mg/m^2^ qwk^g^ (NR for other concurrently used agents) -NR | NR
De Rook, 2008(69) (Belgium) | -113 -Retrospective multi-center cohort -Convenience sampling | -Metastatic EGFR expressing colorectal adenocarcinoma receiving cetuximab treatment (monotherapy or in combination with irinotecan) | 60 [11]^h^ (70) | -NR -Metastatic disease 113 (100) | 0 | -Irinotecan-based therapy | -Cetuximab monotherapy, 30 (27); cetuximab +irinotecan, 83 (73) -NR | 94 (25–473)^i^
Di Nicolantonio, 2008(71) (Italy, Switzerland) | -113 -Retrospective 2-center cohort study, 63 of the patients participated in clinical trials -Convenience sampling | -Histologically confirmed, EGFR expressing metastatic colorectal cancer -Evidence that the treatment outcome could be attributable only to panitumumab or cetuximab | 63 [NR] (64) | -Colon, 70 (62); rectum, 43 (38) -Metastatic disease (100) | 12 | -100 patients (88) had received prior adjuvant chemotherapy; 53 (47) had received 2 prior lines of chemotherapy; 35 (31) had received 3 or more | -Cetuximab monotherapy, 36 (32); panitumumab monotherapy, 26 (23); cetuximab + chemotherapy, 51 (45) -NR | NR
Freeman, 2008(73) (Multinational) | -62 -Retrospective analysis of multi-center cohort^j^ -Convenience sampling | -Metastatic colorectal cancer, disease progression on chemo, tumor samples available for analysis. | 62 [29–85] (60) | NR | 0 | -Fluoropyrimidine, irinotecan, and/or oxaliplatin | -Panitumumab 6 mg/kg q 2 wk or 2.5 mg/kg q 1 wk -NR | NR
Goncalves, 2008(76) (France) | -32 -Retrospective cohort study -Convenience sampling | -EGFR positive metastatic colorectal cancer treated with cetuximab at a single center | 58 (36–78) (50) | -Colon, 21 (65); rectum, 11 (35) -NR | 6 | -Irinotecan 29 (91); none 2 (6); fluoropyrimidine and oxaliplatin 1 (3) | -Cetuximab (loading dose 400 mg/m2 followed by 250 mg/kg weekly) + irinotecan (180 mg/m2 every other week), 26 (81); cetuximab dose escalation in irinotecan refractory patients, 3 (9); cetuximab+FOLFIRI, 3 (9) NR | 19.1 [NR]
Lievre, 2008(79) (France) | -89^k^ -Retrospective multi-center cohort -Convenience sampling | -Histologically confirmed metastatic adenocarcinoma -Treated with cetuximab as US FDA administration guidelines -Treatment response assessable | NR | NR | 0 | -Irinotecan-based chemotherapy | -Cetuximab alone 2 (2); cetuximab + irinotecan 79 (88); cetuximab + FOLFIRI 9 (10) -NR | 10
Lurje, 2008(83) (Multinational) | -130 -Retrospective analysis of phase II study -Convenience sampling | -Metastatic CRC, failed two prior regimens or adjuvant therapy plus one regimen | ≤54 y, 36; 54–64 y, 45; ≥65 y, 49 [NR] (49) | -Colon 99 (76); rectum 31 (24) -Metastatic disease 130 (100) | 0 | -Number of prior regimens: 2–3, 58 (45); 4–5, 60 (46); 6–8, 12 (9) -Patients were refractory to irinotecan, oxaliplatin and fluoropyrimidines | -Cetuximab 400 mg/m^2^ loading dose followed by 250 mg/m^2^ weekly^l^ -NR | 12
Personeni, 2008 (108) (Belgium) | -96 (of whom 87 were tested for KRAS mutations) -Retrospective cohort study (4 centers) -Convenience sampling | -Patients with metastatic colorectal cancer treated at 4 Belgin centers, patients were participants in prospective studies of cetuximab treatment | 59 [26–80] (56) | -NR -Metastatic disease 96 (100) | 0 | -Cetuximab was administered as third-or subsequent-line of treatment. | -Cetuximab monotherapy, 18 (21); cetuximab + irinotecan, 69 (79). Cetuximab loading dose 400 mg/m^2^ followed by 250 mg/m^2^ weekly, 75 (86); cetuximab dose escalation (up to 500 mg/m^2^), 12 (14). | NR
Bibeau, 2009(67) (France) | -69 -Retrospective cohort study (2 centers) -Convenience sampling | -Irinotecan-based chemotherapy-refractory patients with metastatic colorectal cancer | 60 [23–81] (67) | -Colon, 24 (35); sigmoid, 22 (32%); rectum, 21 (30); other, 2 (3) -Metastatic disease 69 (100) | 0 | -All patients had failed irinotecan-based chemotherapy and 78% had received at least two lines of treatment for metastatic disease | -Cetuximab “standard dosage”+irinotecan, 68 (99); FOLFIRI+cetuximab, 1 (1) -NR | 19.3 [0.3 to 34.4]^m^
Garm Spindler, 2009(75) (Denmark) | -71 -Retrospective single-center cohort -Convenience sampling | -Metastatic colorectal adenocarcinoma refractory to prior fluouropyrimidine, oxaliplatin, and irinotecan regimens , minimum of 3 cycles of chemo, measurable disease by RECIST | 61 [38–77] (52) | -Colon 24 (34); rectosigmoideum 22 (31); rectum 25 (35) -Metastatic Sites 1–2, 33 (46); 3–5, 38 (54) | 0 | -Fluoropyrimidine, oxaliplatin, and irinotecan regimes | -Irinotecan 350mg/m^2^ + cetuximab 400mg/m^2^ loading with weekly 250mg/m^2^ -NR | 8 [2–30]
Jacobs, 2009(97) (Belgium)^n^ | -220 -Retrospective multicenter cohort (patients were enrolled in clinical trials evaluating cetuximab) -Convenience sampling | -Irinotecan refractory colorectal cancer patients with EGFR-expressing tumors | NR [NR] (NR) | -NR -Metastatic disease 220 (100) | 0 | NR | -Irinotecan-based chemotherapy 220 (100) -NR | NR
Laurent-Puig, 2009(98) (France) | -173 -Retrospective multicenter cohort -Convenience sampling | -Irinotecan-refractory metastatic colorectal cancer | NR [NR] (NR) | -NR -Metastatic disease 173 (100) | <1 | -Number of previous lines of treatment: none 1 (<1); 1, 13 (8); 2, 78 (45); 3, 49 (28); 4, 20 (12); 5 or more, 12 (7) | -Cetuximab + irinotecan 141 (82); cetuximab + FOLFIRI 28 (16); cetuximab alone 3 (2)^o^ -NR | NR
Loupakis, 2009(82) (Italy) | -102 -Multi-center Retrospective cohort -Convenience sampling | -Measurable and evaluable EGFR+ adenocarcinoma -Progressed ≤3 mo after start of irinotecan-based regimens -Received salvage cetuximab-irinotecan regimen -Paraffin-embedded samples from primary and/or metastatic lesions available^i^ | 62 [38–78] (59) | -NR -84 (82) had multiple metastatic sites; 12 (12) had only hepatic metastasis | 0 | -Irinotecan-based regimens | -Irinotecan 130–180 mg/m^2^ q2wk + cetuximab 250 mg/m^2^ qwk^p^ (only 2 received cetuximab monotherapy) -NR | 21
Loupakis, 2009(81) (Italy) | -138^q^ -Multi-center Retrospective cohort -Convenience sampling | -Measurable and evaluable EGFR+ adenocarcinoma -Progressed ≤3 mo after start of irinotecan-based regimens -Received salvage cetuximab-irinotecan regimen -Paraffin-embedded samples from primary lesions available | 61 [42–77] (55) | -NR -105 (76) had multiple metastatic sites | 0 | -Irinotecan-based regimens | -Irinotecan 180 mg/m^2^ q2wk + cetuximab 250 mg/m^2^ qwk^r^ -NR | NR
Molinari, 2009(84) (Switzerland) | -12^s^ -Single-center retrospective cohort -Convenience sampling | -Metastatic colorectal cancer (adenocarcinoma) -Both synchronous and metachronous metastasis -Registered in a local cancer database | 67 [48–94] (63)^t^ | -Colon (76); Rectum (24) -Synchronous metastases (66); metachronous metastases (34) | 8 | -Irinotecan-based chemotherapy | -Cetuximab alone 11 (92); Cetuximab + irinotecan 1 (8) -NR | NR
Muro, 2009(86) (Japan) | -52^u^ -Retrospective analysis of multi-center Phase II study -Convenience sampling | -CRC with progressive disease after Fluoropyrimidine, irinotecan, and/or oxaliplatin -At least one lesion >20mm in diameter, EGFR expression on >1% of tumor cells | 59 [23–77] (65) | -Colon 30 (58); rectal 22 (42) -Metastatic disease 52 (100) | 0 | -Fluoropyrimidine, irinotecan, and/or oxaliplatin | -Panitumumab at 6mg/kg q 2 wks -Panitumumab dosing: median 6 infusions (range, 2–20) | 26 [5–42]
Oden-Gangloff, 2009(87) (France) | -64 -Retrospective cohort study -Convenience sampling | -Chemorefractory metastatic colorectal cancer patients treated with cetuximab based chemotherapy for whom tissue was available for genotyping | 60 [20–82]^v^ (70) | -NR -Metastatic disease 64 (100) | 0 | -Patients had received a mean of 2 previous chemotherapy regimens (in metastatic setting) and 90% were refractory to irinotecan-based treatment | -Cetuximab + irinotecan or oxaliplatin based chemotherapy 63 (98); cetuximab monotherapy 1 (2) -NR | NR
Paule, 2009(99) (France) | -23 -Retrospective cohort study -Convenience sampling | -Primary EGFR-expression positive colorectal cancer with liver metastases -Resistant to irinotecan | 60 [29–80] (65) | -Colon 23 (100) -Metastatic disease | 0 | -Irinotecan-based chemotherapy 23 (100) | -Cetuximab (loading dose 400 mg/m2 followed by 250m/m2 weekly) + irinotecan (350 mg/m2 every for 6 cycles), 23 (100) -NR | NR
Perrone, 2009(88) (Italy) | -32 -Single-center retrospective cohort -Convenience sampling | Metastatic colorectal cancer Refractory to irinotecan^w^ | 58 [36–78] (63) | -NR -Stage IV at diagnosis23 (72) and metachronous metastasis 9 (28) (NR) | 0 | 5FU or fluoropyrimidines, oxaliplatin, irinotecan | -Irinotecan 300 mg/m^2^ q3wk + cetuximab 250 mg/m2 qwkx -NR | NR
Prenen, 2009(89) (Belgium) | -200 -Retrospective single center cohort 197 of the patients participated in clinical trials -Convenience sampling | -Metastatic colorectal adenocarcinoma receiving cetuximab treatment (monotherapy or in combination with irinotecan) | 61 [26–89] (60) | -NR -Metastatic 200 (100) | 0 | -Irinotecan-based therapy | -Cetuximab monotherapy, 16 (8); cetuximab +irinotecan, 184 (92)^y^ -NR | NR
Sartore-Bianchi, 2009(100) (Italy) | -132 -Retrospective cohort study -Convenience sampling | -Metastatic EGFR-expression positive colorectal cancer -“Evidence that treatment outcome could be attributable to administration of panitumumab or cetuximab” | 63.5 [26–85] (65) | -Colon 78 (59); Rectum 31 (23); Recto-sigmoid junction 19 (14); other 4 (3) -Metastatic disease 132 (100) | 10 | -Number of previous lines of treatment: none 13 (10); 1, 19 (14); 2, 65 (49); 3, 29 (22); 4 or more, 6 (5) -Irinotecan-based chemotherapy 117 (89); luoropyrimidine/capecitabine-based chemotherapy 115 (87); oxaliplatin-based 105 (80) | -Cetuximab + irinotecan-based chemotherapy 94 (71); panitumumab monotherapy 23 (17); cetuximab monotherapy 15 (11) -NR | NR
Sohn, 2009(101) (Korea) | -66 -Retrospective cohort study -“Prospective patients” -Convenience sampling (2 patients were excluded based on tissue availability) | -Histologically confirmed metastatic colorectal cancer that had received at least one course of irinotecan-based chemotherapy -Had experienced disease progression during prior irinotecan-based chemotherapy or within 3 months | 58 [28–77] (61) | -NR -Metastatic disease 66 (100) | 0 | -Number of previous lines of treatment: 1, 2 (3); 2, 22 (33); 3, 42 (64) | -Cetuximab + FOLFIRI 50 (76); cetuximab + irinotecan 16 (24) -NR | NR
Souglakos, 2009(102) (USA + Greece) | -92^z^ -Retrospective cohort study; patients were treated in the USA and Greece -Convenience sampling | -Histologically confirmed metastatic colorectal cancer -Colectomy samples available for molecular analysis | 59 [23–86] (52)^aa^ | -Colon 135 (80); rectum 33 (20)^bb^ -Metastatic disease 92 (100)^cc^ | 0 | -Number of previous lines of treatment: 1, 37 (40); ≥2, 55 (60) | -Cetuximab + chemotherapy -NR | NR
Sartore-Bianchi, 2009(90) (Italy, Switzerland) | -110 -Retrospective single center cohort study -Convenience sampling | -EGFR expressing metastatic colorectal cancer | 64 [26–85] (65) | -Colon, 69 (63); sigmoid, 11 (10); rectum, 28 (25); other, 2 (2) -Metastatic disease (100) | 12^dd^ | -Irinotecan-based, 95 (86); fluoropyrimidine/ capecitabine-based, 93 (85); oxaliplatin-based, 84 (76) | -Panitumumab monotherapy, 22; Cetuximab monotherapy, 14; Cetuximab + irinotecan-based chemotherapy, 74 -NR | NR
Chung, 2010(103) (USA) | -88 -Retrospective cohort study of patients enrolled in a clinical trial of cetuximab monotherapy -Convenience sampling | -Metastatic colorectal cancer -Patients had to have material for KRAS mutation analysis and a mass-spectrometry derived proteomic profile (64/88 patients) | 57 [NR] (57)^ee^ | -Colorectal cancer 88 (100) -Metastatic disease | 0 | NR | -Cetuximab loading dose 400mg/m^2^, followed by 250mg/m^2^ weekly, eligible for dose escalation q 3 wk up to max of 400mg/m^2^ -NR | NR
Graziano, 2010(104) (Italy) | -138 (4 patients had non-assessable samples and 13 were found to carry BRAF mutations and were excluded) -Retrospective cohort study -Convenience sampling | -Metastatic EGFR-expression positive colorectal cancer resistant to irinotecan-based chemotherapy -Available tumor from the primary cancer | 65 [41–77] (54) | -NR -Metastatic disease 138 (100) | 0 | -All patients had failed prior irinotecan-based chemotherapy -Treatment in the study was “third line” | -Cetuximab (loading dose 400 mg/m2 followed by 250 mg/kg weekly) + irinotecan (180 mg/m2 every other week), 138 (100) -NR | NR
Montagut, 2010(106) (Spain) | -48 -Retrospective single center cohort study -“consecutive patients” -Convenience sampling (based on tissue availability) | -Histologically confirmed metastatic colorectal cancer -Available tissue for molecular analysis | <65 y, 26; ≥65 y, 22 [NR] (65) | -Colon 36 (75); rectum 12 (25) -Metastatic disease 48 (100) | 2 | -47 (98) of patients had failed prior chemotherapy - Number of previous lines of treatment: 1, 7 (15); ≥2, 40 (83) | - Cetuximab (loading dose 400 mg/m2 followed by 250 mg/kg weekly) + chemotherapy [irinotecan-based, 44 (92); oxaliplatin-based 4 (8)] -NR | NR
Perkins, 2010(105) (France) | -42 -Retrospective cohort study -Convenience sampling | -Histologically proven, EGFR-expression positive metastatic colorectal adenocarcinoma | 61 [44–78] (57) | -NR -Metastatic disease 42 (100) | 2 | -Number of previous lines of treatment: none, 1 (2); 1, 16 (38); 2, 17 (40); 3, 5 (12); 4 or more 3 (7) | -Cetuximab + irinotecan 37 (88); cetuximab + FOLFIRI 2 (5); cetuximab alone 2 (5); panitumumab alone 1 (2) -NR | 10 [NR]
Scartozzi, 2010(107) (Italy) | -112 -Retrospective cohort study -Convenience sampling | -Histologically proven EGFR-expression positive metastatic colorectal cancer -Previous treatment with irinotecan -Progressive disease under irinotecan-based chemotherapy | 64 [36–81] (63) | -NR -Metastatic disease 112 (100) | 0 | -Number of previous lines of treatment: 1, 13 (12); 2–3, 99 (88) -All patients had received prior oxaliplatin-based chemotherapy | -Cetuximab + FOLFIRI 36 (32); cetuximab + irinotecan 76 (68) -NR | NR

a Number of included patients typically assessed for baseline clinical characteristics, not necessarily the same as the number assessed for KRAS mutations.

b It is unclear whether the assessment of KRAS mutations was also prospectively planned.

c 11 patients had not received any chemotherapy regimen for metastatic disease. Adjuvant chemotherapy data were not reported.

d Percentage of patients receiving first line treatment for metastatic disease. The percentage of patients who had received adjuvant chemotherapy was not reported.

e Line of treatment for metastatic disease.

f It is unclear the assessment of KRAS mutations were also prospectively planned.

g 400 mg/m^2^ for the first week.

h Mean [SD].

i Time since diagnosis of metastatic disease.

j Pooled retrospective analysis of 3 Phase II trials.

k 114 patients are assessed in a pooled analysis.

l Data extracted from Lenz et al., J Clin Oncol, 2006.

m Median follow-up [95% confidence interval].

n This study also included a small (n=67) cohort from France that received standard treatment for colorectal cancer. All patients in this cohort were WT for KRAS mutations. We did not extract data for these patients.

o Treatment was not reported for one patient.

p 400 mg/m^2^ for the first week, and 500 mg/m^2^ if administered every 2 weeks.

q KRAS 12, 13, 61, and 146 mutations were assessed. 76 patients assessed for KRAS 61 and 146 mutations only.

r 400 mg/m^2^ for the first week, and 500 mg/m2 if administered every 2 weeks.

s Those who received cetuximab only. Other 26 patients did not receive cetuximab.

t Data extracted from the entire cohort including those who did not receive cetuximab.

u Only 16 samples available for KRAS genotyping. This was augmented with 8 additional samples from another Phase 1 panitumumab study in patients with metastatic disease for a total of 24 KRAS samples

v Mean age [range].

w Refractory to irinotecan was defined as disease progression during treatment or <3 months of the end of the last received cycle.

x 400 mg/m^2^ for the first week

y 197 (98.5%) of patients were participants in clinical trials evaluating cetuximab monotherapy or cetuximab+irinotecan-based combinations.

z The study enrolled a total of 168 patients of whom 100 received cetuximab in combination with chemotherapy. Of those 100, 92 received this treatment in the second-line setting and the study reports clinical outcomes only for them.

aa Data refer to the overall cohort (168 individuals).

bb Data refer to the overall cohort (168 individuals).

cc Data refer to the overall cohort (168 individuals).

dd Individuals that received no previous cancer treatments for advancd disease prior to anti-EGFR antibody treatment.

ee Data refer to the overall cohort (88 individuals).

BSA, body surface area; BSC, best-supportive care; CAPOX, capecitabine, oxaliplatin; CB, capecitabine, oxaliplatin, bevacizumab; CBC, capecitabine, oxaliplatin, bevacizumab, cetuximab; CNS, central nervous system; CPT-11, irinotecan; EGFR, epidermal growth factor receptor; FISH, fluorescence in situ hybridization; FOLFIRI, irinotecan, fluorouracil, and folinic acid; FOLFOX, oxaliplatin, fluorouracil, and folinic acid; IAH, intra-artery hepatic infusion; IHC, immunohistochemistry; LV5FU2, leucovorin, 5-fluorouracil; NA, not applicable; NR, not reported; PS, performance status; WHO, World Health Organization.

### Mutation testing characteristics

The methods and results of KRAS mutation analyses are presented in Tables 10 and 11. The majority of studies only assessed codons 12 and 13 of the KRAS gene, using direct sequencing or allele-specific methods. The commonly employed technologies are commercially available.

Table 10 KRAS and anti-EGFR antibodies for colorectal cancer: detection and reporting of mutations (first line therapy)

Study (first author, year) | Number tested [Number enrolled]^a^, n | Tumor site, n (%) [Source, time between collection and DNA extraction, h] | Mutation detection method | Detection ability (%) | Mutation Frequency, n (%) | | | | | | | Comment
Study (first author, year) | Number tested [Number enrolled]^a^, n | Tumor site, n (%) [Source, time between collection and DNA extraction, h] | Mutation detection method | Detection ability (%) | Exon 1 | | | | | | Exon 2 | Wild-type (%)
Study (first author, year) | Number tested [Number enrolled]^a^, n | Tumor site, n (%) [Source, time between collection and DNA extraction, h] | Mutation detection method | Detection ability (%) | Codon 12 | | | | | Codon 13 | Codon 61 | Wild-type (%)
Study (first author, year) | Number tested [Number enrolled]^a^, n | Tumor site, n (%) [Source, time between collection and DNA extraction, h] | Mutation detection method | Detection ability (%) | C34 G>A (G12S) | C34 G>T (G12C) | C35 G>A (G12D) | C35 G>C (G12A) | C35 G>T (G12V) | C38G>A (G13D)
Randomized controlled trials
Bokemeyer, 2009 | 233 [344] | NR [PET, NR] | PCR clamping and melting curve | NR | NR | NR | NR | NR | NR | NR | Not assessed | 134 (58) of whom 61 received cetuximab | Any mutation+ 99 (42%) of whom 52 were in the cetuximab arm
Hecht, 2009 | 865 [1053] | NR [PET, NR] | ARMS-PCR (DxS) | NR | 346 (40) | | | | | | Not assessed^b^ | 519 (60) of whom 258 received panitumumab
Tol, 2009 | 520 [755] | P 520 (100) [PET, NR] | ARMS-PCR (DxS) | 1% | NR | NR | NR | NR | NR | NR | Not assessed | 314 (60) | 7 most prevalent KRAS mutations in codon 12 (n=6) and 13 (n=1) were assessed 206 (40%) had KRAS mutation.
Van Cutsem, 2009 | 540 [1217] | NR [PET, NR] | PCR clamping and melting curve | NR | NR | NR | NR | NR | NR | NR | Not assessed | 348 (64) of whom 172 received cetuximab | Any Mutation+ 192 (36%) of whom 105 were in the cetuximab arm
Folprecht, 2010^c^ | 99 [111]^d^ | P 44 (44) & M 55 (56) [PET] | ARMS-PCR (DxS) & DS | NR | 29 (29) | | | | | | Not assessed | 70 (71)
Single arm studies
Bengala, 2009 | 39^e^ | P [Microdissected PET, NR] | Bi-DS | NR | 9 (23) | | | | | | Not assessed | 30 (77)
Debucquoy, 2009 | 40 | P [PET, NR] | AS-Taqman allelic discriminatory assay | NR | NR | NR | NR | NR | NR | NR | Not assessed | 27 (69) | Any mutation+ 12 (31%)
Yen, 2009^f^ | 76 [76] | P 76 (100) [FFT, NR]^g^ | DS on tumor samples, membrane array on peripheral blood | NR | NR | NR | NR | NR | NR | NR | NR | Tumor: 43 (57) Blood: 46 (61) | Any mutation+ 33 (43%) Tumor: Codon 12, 11 (33%); Codon 13, 9 (27%); Codon 15, 7 (21%); Codon 18, 1 (3%); Codon 20, 2 (6%); Codon 30, 2 (6%); Codon 31, 1 (3%) Blood: mutations in codons 12,13,15,18 no reported individually Membrane array compared to primary tumor sequence data: sensitivity = 84%, specificity=95%.
Tabernero, 2010 | 48 [62] | NR [PET] | PCR clamping and melting curve technique | NR | 0 | 0 | 4 (8) | 1 (2) | 9 (19) | 5 (10) | Not assessed | 29 (60)
Yen, 2010^h^ | 95 [95] | P 95 (100) [PET, FFT] | DS^i^ | NR | 23 (24) | | | | | | Not assessed | 72 (76) | The study also assessed mutations in codons 15, 18, 20, 30 and 31. Overall, 41 mutations (43%) were identified. Mutations in codons 12, 13, 15 and 18 (33 mutations, 35%) were considered as “activating”.

a The number of patients who were enrolled into a trial and randomized (randomized clinical trials only).

b The mutations assessed by the employed Method were extracted from Amado, J Clin Oncol, 2008.

c All patients received cetuximab.

d Of whom 94 were assessable for response.

e The patient who did not undergo surgery (and was excluded from all analyses of response) did not have a KRAS mutation.

f Although not reported in the paper, the authors confirmed that this was a “first-line study”.

g Patients’ RNA was also isolated from peripheral blood samples.

h Although not reported in the paper, the authors confirmed that this was a “first-line study”.

i Data extracted from Yen, Clin Cancer Res, 2009.

ARMS, amplification refractory mutation system; AS-PCR, allele-specific PCR; b-DS, bi-directional direct sequencing; DS, direct sequencing; LN, lymph node metastasis; LCR, Ligase chain reaction; M, metastatic tumor; NR, not reported; P, primary tumor; PCR, polymerase chain reaction; PET, paraffin-embedded tissue; PS, pyrosequencing.

Table 11 KRAS and anti-EGFR antibodies for colorectal cancer: detection and reporting of mutations (salvage therapy)

Study (first author, year) | Number tested [Number enrolled]^a^ , n | Tumor site, n (%) [Source, time between collection and DNA extraction, h] | Mutation detectio n method | Detection ability (%) | Mutation Frequency, n (%) | | | | | | | | Comment
Study (first author, year) | Number tested [Number enrolled]^a^ , n | Tumor site, n (%) [Source, time between collection and DNA extraction, h] | Mutation detectio n method | Detection ability (%) | Exon 1 | | | | | | Exon 2 | Wild-type (%) | Comment
Study (first author, year) | Number tested [Number enrolled]^a^ , n | Tumor site, n (%) [Source, time between collection and DNA extraction, h] | Mutation detectio n method | Detection ability (%) | Codon 12 | | | | | Codon 13 | Codon 61 | Wild-type (%) | Comment
Study (first author, year) | Number tested [Number enrolled]^a^ , n | Tumor site, n (%) [Source, time between collection and DNA extraction, h] | Mutation detectio n method | Detection ability (%) | C34 G>A (G12S) | C34 G>T (G12C) | C35 G>A (G12D) | C35 G>C (G12A) | C35 G>T (G12V) | C38G>A (G13D) | | Wild-type (%) | Comment
Randomized controlled trials
Amado, 2008^b^ | 427 [463] | “Mostly” from P 410 (96) [PET, NR] | AS-PCR | NR | 14 (3) | 14 (3) | 70 (16) | 15 (4) | 40 (22) | 29 (16) | Not assessed | 243 (60) | Any mutation+ 184 (43%)
Karapetis, 2008 | 394 [572] | NR | DS 2 | NR | 17 (10) | 9 (5) | 61 (36) | 11 (6) | 48 (28) | 20 (12) | Not Assessed | 164 (42) | “Exon 2” sequenced. Any mutation+ 230 (58%) Other mutations noted: G12R: 2 (1); G13A: 1 (1); G13C: 1 (1); G13V: 1 (1)
Single arm studies
Moroni, 2005 | 31 | NR [PET, NR] | DS | NR | 1 (3) | 0 | 3 (10) | 0 | 2 (6) | 4 (13) | Not assessed | 21 (68) | Any mutation+ 10 (32%)
Lievre, 2006 | 30 | P 30 (100) [FFT, NR] | DS | NR | 1 (3) | 2 (7) | 5 (17) | 1 (3) | 1 (3) | 3 (10) | Not assessed | 17 (57) | Exon 1 was assessed
Benvenuti, 2007 | 48 | NR [PET] | DS | NR | | | 10 (21) | | | 6 (14) | Not assessed | 32 (67)
Di Fiore, 2007 | 59 | P 53 (90); M 6 (10) [PET, NR] | DS only, DS + SNaPshot assay + PCR-LCR^c^ | NR | NR | NR | NR | NR | NR | NR | Not assessed | 43 (73); 37 (63)^d^ | “Exon2” was examined 16 (27%) or 22 (37%)^e^ had KRAS mutations.
Frattini, 2007 | 27 | P (100) [PET] | Bi-DS | NR | 0 | 1 (4) | 4 (15) | 2 (7) | 0 | 3 (11) | Not assessed | 17 (63)
Khambata-Ford, 2007 | 80 | M 80 (100) [FFT, NR] | DS 2 | NR | NR | NR | NR | NR | NR | NR | Not assessed | 50 (63) | “Exon 2” sequenced, but no specific mention of identified variants Any mutation+ 30 (38%)
Cappuzzo, 2008 | 80 | P 65 (76); M 20 (24) [NR] | Surveyor® DNA endonuclease | NR | NR | NR | NR | NR | NR | 8 (10) | NR | 38 (48) | Any mutations 42 (53%) “Exons 1 and 2” were assessed
De Rook, 2008^f^ | 113 | NR (100) [PET, NR] | Allelic discrimination assay and bi-DS | NR | 4 (4) | 3 (3) | 17 (15) | 3 (3) | 10 (9) | 9 (8) | Not assessed | 67 (59) | Any mutation+ 46 (41%)
Di Nicolantonio, 2008 | 113 | NR [PET, NR] | DS | NR | NR | NR | NR | NR | NR | NR | Not assessed | 79 (70) | Any mutation+ 34 (30%)
Freeman, 2008 | 62 | NR | DS | NR | NR | NR | NR | NR | NR | NR | 0 | 38 (61) | Exon 2 was also sequenced Any mutation+:24 (39%) in either codon 12 or 13
Goncalves, 2008 | 32 | P and/or M [12, PET; 20 FT, NT] | DS | NR | 0 | 1 (3) | 6 | 0 | 3 (9) | 4 (13) | Not assessed | 18 (56) | Any mutation+ 14 (44%)
Lievre, 2008 | 114^g^ | P 83 (73); M 31 (27) [FFT or PET, NR] | TaqMan® allelic discrimination assay^h^ | 20 | NR | NR | NR | NR | NR | Not assessed | Not assessed | 65 (73) | 24 patients (27%) had mutation in KRAS gene.
Lurje, 2008 | 130 | NR | DS 12, 13 | NR | NR | NR | NR | NR | NR | NR | Not assessed | 88 (68) | Any mutation+ 42 (32%)
Personeni, 2008 | 87 [96] | NR [PET, NR] | Allelic discrimination assay | NR | 29 (33) | | | | | | Not assessed | 58 (67)
Bibeau, 2009 | 64 | P (77), M (22), Local (1) [PET, NR] | Multiplex primer extension method sequencing | NR | NR | NR | NR | NR | NR | NR | Not assessed | 37 (58) | Any mutation+ 27 (42%)
Garm Spindler, 2009 | 64 | P & M 31 (48) P 33 (52) [PET, NR] | DxS qPCR kit (7 mutations in codons 12 and 13) | NR | NR | NR | NR | NR | NR | NR | Not assessed | 42 (66) | Samples from 59 patients were also assessed with DS. Any mutation+ 22 (34%)
Jacobs, 2009 | 212 [220] | NR [NR] | Allelic discrimination assay and bi-DS | NR | 91 (43) | | | | | | Not assessed | 169 (80)
Laurent-Puig, 2009 | 169 [173] | NR [FFT or PET, NR]^i^ | TaqMan® allelic discrimination assay^j^ | 20 | 53 (31) | | | | | | Not assessed | 116 (69)
Loupakis, 2009 | 93 | P&M 43 (46); P 45 (48); M 5 (5) [PET, NR] | DS 12/13 | NR | NR | NR | NR | NR | NR | NR | Not assessed | 53 (60); 27 (56)^k^ | 2 out of 43 (5%) patients with samples form both primary and metastatic lesions available and evaluable had discrepant test results between primary and metastatic tumor. 35 (40%) and 21 (48%) had KRAS mutation in primary (total n=88) and metastatic (total n=48) tumors, respectively. PTEN (by immunohistochemistry) was also assessed and outcome results were also presented with any KRAS mutations and PTEN positive vs. negative.
Loupakis, 2009 | 138 | P 138 (100) [PET, NR] | PS | NR | NR | NR | NR | NR | NR | NR | 7 (5) | 79 (57) | 51 (37%) had KRAS mutations in codon 12 or 13. 1 (0.7%) had KRAS mutation in codon 146. Only codons 12, 13, 61, and 146 were examined BRAF mutations were also assessed and outcome results were also presented by any KRAS 61 or 146 or BRAF mutations positive vs. negative.
Molinari, 2009 | 12 | P&M&LN 5 (42); P&M 7 (58) [PET, NR] | DS | NR | 1 (8) | 0 | 1 (8) | 3 (25) | 0 | 0 | Not assessed | 7 (58) | All 5 patients with mutation in the KRAS gene had concordant results between primary and metastatic tumor, and lymph node metastasis.
Muro, 2009 | 24 | NR | DxS | NR | NR | NR | NR | NR | NR | NR | Not assessed | 14 (58) | Any mutation+: 10 (42)
Oden-Gangloff, 2009^l^ | 64 | NR [PET 55 (86); FFT 9 (14), NR] | Multiplex primer extension method sequencing | NR | 1 (2) | 2 (3) | 3 (5) | 1 (2) | 5 (8) | 5 (8) | Not assessed | 46 (72) | Any mutation+ 18 (28%)
Paule, 2009 | 19 [23] | NR [PET, NR] | TaqMan® allelic discrimination assay | NR | 3 (16) | | | | | | Not assessed | 16 (84)
Perrone, 2009 | 29 | P&M 12 (38); P 12 (38); M 8 (25) [PET, NR] | DS | NR | 1 (3) | 0 | 3 (10) | 0 | 1 (3) | 2 (7) | Not assessed | 22 (76) | 2 out of 7 patients with mutation in the KRAS gene had discrepant test results between primary and metastatic tumor. Any mutation+ 7 (24%)
Prenen, 2009 | 199 | P 199 (100) [PET, NR] | AS-PCR | NR | NR | NR | NR | NR | NR | NR | Not assessed | 122 (61) | Any mutation+ 77 (39%)
Sartore-Bianchi, 2009^m^ | 109 | P or liver M [PET, NR] | DS | NR | 5 (5) | 1 (1) | 8 (7) | 5 (5) | 5 (5) | 8 (7) | Not assessed | 77 (71) | Any mutation+ 32 (29%)
Sartore-Bianchi, 2009 | 131 [132] | P 130 (98); M 2 (2) [PET, NR] | DS | NR | 35 (27) | | | | | | Not assessed | 96 (73)
Sohn, 2009 | 66 [68] | P 62 (94); M 4 (6) [PET, NR] | DS | NR | 21 (32) | | | | | 6 (9) | Not assessed | 39 (59)
Souglakos, 2009 | 92 [92] | P 92 (100) [PET, NR] | Sequenom mass-spectrometric genotyping (USA) and Sanger DS (Greece); results were cross-confirmed | NR | 32 (35) | | | | | | Not assessed | 60 (65)
Chung, 2010^n^ | 64 [88] | M 66 (100) [FFT, NR] | DS | NR | 26 (41) | | | | | | Not assessed | 38 (59)
Graziano, 2010 | 134 [138] | P 134 (100) [PET, NR] | Pyrosequencing | NR | 58/121 (48)^o^ | | | | | | | 63 (52) | No data is presented regarding the 13 BRAF mutation carriers.
Montagut, 2010 | 48 [48] | NR [PET, NR] | DS | NR | 0 | 0 | 3 (6) | 1 (2) | 3 (6) | 5 (10) | Not assessed | 36 (75)
Perkins, 2010 | 42 [42] | P & M [FFT or PET, NR] | TaqMan® allelic discrimination assay^p^ | 20 | 19 (45) | | | | | | Not assessed | 23 (55)
Scartozzi, 2010 | 112 [112] | P 112 (100) & M NR (NR) [PET, NR] | DS | NR | 6 (5) | 0 | 13 (12) | 5 (4) | 5 (4) | 10 (9) | Not assessed | 69 (62) | Also detected 4 patients (4%) with codon 12 G12R mutations

a The number of patients who were enrolled into a trial and randomized (randomized clinical trials only).

b Three patients had the G12R KRAS mutation. One patient carried two mutations (G12D and G12R).

d The former is for DS only, and the latter for DS partially (95% of patients) complimented by SNaPshot assay and PCR-LCR.

e The former is for DS only, and the latter for DS partially (95% of patients) complimented by SNaPshot assay and PCR-LCR.

c SNaPshot assay and PCR-LCR as complement to DS was performed in 41 (95%) out of 43 patients with no mutation detected by DS.

f One patient carried two mutations (G12S and G12V).

g “Pooled” cohort.

h All identified mutations were verified with DS.

i Mutation detection was described in Lievre, J Clin Oncol, 2008.

j All identified mutations were verified with DS.

k The former is primary tumor (total n=88) and the later.

l One patient carried the G13C (c37G>T) mutation.

m One patient carried two mutations (G12R and G13D). In addition one patient carried the G13V mutation.

n Data extracted from Khambata-Ford, J Clin Oncol, 2007.

o Four patients had non-assessable samples. In addition, 13 patients carrying BRAF mutations were excluded from all outcomes reported in the study pertain to 121 patients.

p All identified mutations were verified with DS.

ARMS, amplification refractory mutation system; AS-PCR, allele-specific PCR; b-DS, bi-directional direct sequencing; DS, direct sequencing; FFT= fresh frozen tissue; LN, lymph node metastasis; LCR, Ligase chain reaction; M, metastatic tumor; NR, not reported; P, primary tumor; PCR, polymerase chain reaction; PET, paraffin-embedded tissue; PS, pyrosequencing.

### Key Question 1 Does KRAS testing predict response to cetuximab or panitumumab therapy?

All but two studies evaluated the association of KRAS testing results with clinical outcomes in patients with colorectal cancer in the metastatic setting and their results are summarized bellow. Two studies evaluated the association of KRAS with clinical outcomes in the neoadjuvant setting, exclusively for patients with advanced rectal cancer, and are discussed separately at the end of this topic.(65;70)

#### Mortality

##### Strength of the association between KRAS testing results and mortality

Tables 12 and 13 summarize KRAS associations with mortality in the first- and second-line settings, respectively. Only 30 studies reported analyses on overall survival and/or mortality outcomes. In the anti-EGFR antibody treated arms time-to-event analyses were presented in 28 studies. In 15 of those, a statistically significant detrimental effect of KRAS mutations was observed. In all 22 studies that reported relevant information, median overall survival in KRAS positive patients was shorter compared to the median overall survival of wild-type patients. Mortality analyses were presented in 5 studies, all of which demonstrated higher mortality risk in KRAS mutated patients although data were sparse and confidence intervals were wide.

As previously mentioned, 7 of the studies were based on RCTs. Of those, 2 studies assessed the treatment-by-KRAS mutation interaction. The test was statistically significant in the study by Karapetis 2008.(59) (p=0.01) indicating that difference between the anti-EGFR antibody treatment arm and the comparator arm was present in the wild-type group of patients but not the group of patients harboring KRAS mutations. The interaction test was non-significant in the study by van Cutsem 2009 (p=0.44) but the direction of effects was consistent.(61)

Table 12 KRAS and cetuximab for colorectal cancer: mortality (first line therapy)

Author, year | Study arm (patient number) | Event/patient, n (%) | | OR (95% CI) | P value | Median Survival Time, mo | | HR (95% CI) | P value
Author, year | Study arm (patient number) | Mutation+ | Mutation− | OR (95% CI) | P value | Mutation+ | Mutation− | HR (95% CI) | P value
Randomized controlled trials
Bokemeyer, 2009^a^ | FOLFOX-4 + cetuximab | NR | NR | NR | NR | NR | NR | NR | NR
| FOLFOX-4 | NR | NR | NR | NR | NR | NR | NR | NR
Hecht, 2009 (Multinational) | ChBP cohort
| Oxaliplatin-based | NR | NR | NR | NR | 19.3 | 20.7 | NR | NR
| Irinotecan-based | NR | NR | NR | NR | 17.8 | “Not estimable”^b^ | NR | NR
| ChB cohort
| Oxaliplatin-based | NR | NR | NR | NR | 19.3 | 24.5 | NR | NR
| Irinotecan-based | NR | NR | NR | NR | 20.5 | 20 | NR | NR
Tol 2009 | CBC (1’) | NR | NR | NR | NR | 17.2 | 21.8 | NR | 0.06
| CB (1’) | NR | NR | NR | NR | 24.9 | 22.4 | NR | 0.82
Van Cutsem, 2009 | FOLFIRI+cetuximab | 83/105 (79) | 104/172 (60) | 2.47 (1.41–4.30) | 0.002 | 17.5 | 24.9 | NR | NR
| FOLFIRI | 65/87 (75) | 115/176 (65) | 1.57 (0.88–2.78) | 0.16 | 17.4 | 21 | NR | NR
Folprecht, 2010 | FOLFOX + cetuximab | NR | NR | NR | NR | NR | NR | NR | NR
| FOLFIRI + cetuximab | NR | NR | NR | NR | NR | NR | NR | NR
Single arm studies
Yen, 2009 | Cetuximab + chemotherapy | NR | NR | NR | NR | NR | NR | 6.67 (2.70–12.50) | <0.0001
Tabernero, 2010 | Cetuximab monotherapy phase | NR | NR | NR | NR | NR | NR | NR | NR
| Cetuximab + FOLFIRI phase | NR | NR | NR | NR | NR | NR | NR | NR
| Overall analysis (full follow-up period) | NR | NR | NR | NR | NR | NR | NR | NR
Yen, 2010^c^ | Cetuximab+ chemotherapy | NR | NR | NR | NR | NR | NR | 6.76 (3.16–14.48) | <0.0001

a Nine patients were not assessable for response in this study.

b Per study report.

c If the analysis is limited to “activating KRAS mutations” (per study definition), the OS HR=9.91 (4.53–21.65).

CI, confidence interval; FOLFIRI, irinotecan, fluorouracil, and folinic acid; FOLFOX, oxaliplatin, fluorouracil, and folinic acid; HR, hazard ratio; NR, not reported; OR, odds ratio.

Table 13 KRAS and anti-EGFR antibodies for colorectal cancer: mortality (Salvage therapy)

Author, year | Study arm (patient number) | Event/patient, n (%) | | OR (95% CI) | P value | Median Survival Time, mo | | HR (95% CI) | P value
Author, year | Study arm (patient number) | Mutation+ | Mutation− | OR (95% CI) | P value | Mutation+ | Mutation− | HR (95% CI) | P value
Randomized controlled trials
Amado, 2008 | Panitumumab + BSC BSC | 79/84 (94) 95/100 (95) | 107/124 (86) 110/119 (92) | 2.51 (0.89–7.09) 1.55 (0.30–4.80) | 0.12 0.62 | 4.9 4.4 | 8.1 7.6 | NR NR
Karapetis, 2008 | Cetuximab BSC | NR NR | NR NR | NR NR | NR NR | 4.5 4.6 | 9.5 4.8 | NR NR | NR NR
Single arm studies
Moroni. 2005 | Cetuximab +/− chemotherapy; panitumumab monotherapy | NR | NR | NR | NR | NR | NR | NR | NR
Lievre, 2006 | Cetuximab-based (Salvage only) | 10/13 (77) | 7/14 (50) | 3.3 (0.50–26.1) | 0.15 | 6.9 | 16.3 | NR | 0.02
Benvenuti, 2007 | Panitumumab or Cetuximab +/− irinotecan | NR | NR | NR | NR | NR | NR | NR | NR
Di Fiore, 2007 | Cetuximab + irinotecan or oxaliplatin | NR | NR | NR | NR | NR | NR | NR | NR
Frattini, 2007 | Cetuximab + chemotherapy | NR | NR | NR | NR | NR | NR | NR | NR
Khambata-Ford, 2007 | Cetuximab | NR | NR | NR | NR | NR | NR | NR | NR
Cappuzzo, 2008 | Cetuximab-based | NR | NR | NR | NR | 9.5 | 10.8 | NR | 0.3^a^
De Rook, 2008 | Cetuximab +/− irinotecan | NR | NR | NR | NR | 6.8 | 10.8 | 1.61 (1.09–2.44) [adjusted]^b^ | 0.020
Di Nicolantonio, 2008 | Cetuximab +/− chemotherapy; panitumumab monotherapy | NR | NR | NR | NR | NR | NR | NR | 0.0869
Freeman, 2008 | Panitumumab | 22/24 (92) | 29/38 (76) | 3.41 (0.67–17.4) | 0.23 | 5.6 | 10.7 | 2.00 (1.11–3.33) | <0.015
Goncalves, 2008 | Cetuximab + chemotherapy; cetuximab | NR | NR | NR | NR | 13.8 | 20.8 | NR | 0.472
Lievre, 2008 | Cetuximab-based (primary data n=88) Cetuximab-based (Pooled analysis n=113) | NR NR | NR NR | NR NR | NR NR | 10.1 10.1 | 14.3 14.3 | NR NR 2.4 (1.4–4.1), [skin toxicity] | 0.026 0.0017 0.001
Lurje, 2008 | Cetuximab | NR | NR | NR | NR | 4.9 | 6.6 | 1.59 (1.05–2.40) | 0.02
Personeni, 2008 | Cetuximba +/− irinotecan | NR | NR | NR | NR | NR | NR | NR | NR
Bibeau, 2009 | Cetuximab + irinotecan-based chemotherapy | NR | NR | NR | NR | 8.7 | 10.8 | 1.6 (0.8–2.9) [adjusted]^c^ | 0.147 0.151 [adjusted]^d^
Garm Spindler, 2009 | Cetuximab + irinotecan | NR | NR | NR | NR | 8.7 | 11.1 | NR | 0.46
Jacobs, 2009 | Cetuximab +/− chemotherapy^e^ | NR | NR | NR | NR | 7 | 11 | NR | NR
Laurent-Puig, 2009 | Cetuximab +/− irinotecan-based chemotherapy | NR | NR | NR | NR | 8.4 | 14.4 | NR | <0.001
Loupakis, 2009 | Cetuximab +/− irinotecan | NR | NR | NR | NR | 6.1 | 13.5 | 2.2 (1.5–4.5) | 0.0004
Loupakis, 2009^f^ | Cetuximab + irinotecan | NR | NR | NR | NR | 9.7 | 14.7 | 1.4 (0.57–4.2) | 0.39
Molinari, 2009 | Cetuximab +/− irinotecan | NR | NR | NR | NR | NR | NR | NR | NR
Muro, 2009 | Panitumumab | NR | NR | NR | NR | NR | NR | NR | NR
Oden-Gangloff, 2009 | Cetuximab + irinotecan-based chemotherapy | NR | NR | NR | NR | NR | NR | NR | NR
Perrone, 2009 | Cetuximab + irinotecan | NR | NR | NR | NR | NR | NR | NR | NR
Prenen, 2009 | Cetuximab +/− irinotecan | NR | NR | NR | NR | 6.5 | 11.3 | 2.00 (1.45–2.70) | <0.0001
Paule, 2009^g^ | Cetuximab + irinotecan | 3/3 (100) | 13/16 (81) | 1.81 (0.08 – 43.99)^h^ | 0.71 | NR | NR | NR | NR
Sartore-Bianchi, 2009 | Cetuximab +/− chemotherapy; panitumumab monotherapy (109) | NR | NR | NR | NR | NR | NR | NR | 0.1127
Sartore-Bianchi, 2009 | Cetuximab +/− irinotecan-based chemotherapy or panitumumab monotherapy | NR | NR | NR | NR | NR | NR | 1.72 (1.017–2.903) | 0.043
Sohn, 2009 | Cetuximab + irinotecan-based chemotherapy | NR | NR | NR | NR | 7 | 18 | 2.42 (1.2–4.7) [adjusted for skin toxicity and number of prior chemotherapy regimens] | 0.001 [log-rank] 0.009 [adjusted for skin toxicity and number of prior chemotherapy regimens]
Souglakos, 2009 | Cetuximab + chemotherapy | NR | NR | NR | NR | NR | NR | NR | NS
Chung, 2010 | Cetuximab | NR | NR | NR | NR | NR | NR | NR | NR
Graziano, 2010 | Cetuximab + irinotecan | NR | NR | NR | NR | NR | NR | 2.3 (1.46–3.7) [adjusted for sex, age, ECOG performance status, number of metastatic sites, CEA levels] | 0.004 [adjusted for sex, age, ECOG performance status, number of metastatic sites, CEA levels]
Montagut, 2010 | Cetuximab + chemotherapy | NR | NR | NR | NR | NR | NR | NR | 0.1
Perkins, 2010 | Cetuximab +/− irinotecan-based chemotherapy or panitumumab monotherapy | NR | NR | NR | NR | 6 | 14 | NR | 0.02
Scartozzi, 2010 | Cetuximab +/− irinotecan-based chemotherapy | NR | NR | NR | NR | 9.5 | 16 | NR | 0.0003

a Subgroup analysis by EFGR by FISH reported.

b Age, gender, skin toxicity, previous chemotherapies, and treatment regimen were used as covariates.

c Covariates used in the multivariate analyses not reported.

d Covariates used in the multivariate analyses not reported.

e Patients were recruited from clinical trials investigating diverse treatment strategies.

f Only codon 61 and 146 were assessed for mutations if patients had no mutations in codon 12 or 13 (n=76).

g Mortality data at 4 years.

h Continuity correction k=0.5 was used to calculate the odds ratio.

BSC, best supportive care; CEA, carcinoembryonic antigen; CI, confidence interval; ECOG, Eastern Cooperative Oncology Group; FISH, fluorescent in situ hybridization; FOLFIRI, irinotecan, fluorouracil, and folinic acid; FOLFOX, oxaliplatin, fluorouracil, and folinic acid; HR, hazard ratio; NR, not reported; NS, non-significant; OR, odds ratio.

#### Progression

##### Strength of the association between KRAS testing results and recurrence

Tables 14 and 15 summarize KRAS associations with disease progression in the first- and second-line settings, respectively. Thirty eight studies reported progression-free-survival or time-to-progression analyses. The outcomes were referred to as “PFS” in 33 of the studies and as “TTP” in 5 of the studies. In all studies reporting disease progression information, median PFS or TTP was shorter among patients with KRAS positive tumors, compared to wild-type patients and the difference was statistically significant in 25 studies.

As previously mentioned, 7 of the studies were based on RCTs, six of which reported on PFS. In the antibody-treated arms of these studies, PFS was shorter among KRAS mutated patients compared to wild-type patients in all cases (and the difference was statistically significant in two of the studies that reported a relevant p-value). The studies by Amado 2008, Karapetis 2008 and van Cutsem 2009 assessed the treatment-by-KRAS mutation interaction test p-value was <0.0001, 0.0001 and 0.07 respectively. Bokemeyer 2009 did not report an interaction test. However, we observed that in cetuximab-treated patients presence of KRAS mutations had a hazard ratio of 2.2, while the corresponding HR in the comparator arm was 0.7. The confidence intervals of these estimates were not overlapping, suggesting a significant interaction between KRAS and treatment. In all three studies, the anti-EGFR antibody treatment appeared to be beneficial for the group of patients with wild type tumors but not the patients whose tumors harbored KRAS mutations.

Table 14 KRAS and cetuximab for colorectal cancer: progression (first line therapy)

Author, year | Study arm (patient number) | Response criteria | PFS vs. TTP Definition | Frequency of F/U | Event/patient, n (%) | | OR (95% CI) | P value | Median Survival Time, mo | | HR (95% CI) | P value
Author, year | Study arm (patient number) | Response criteria | PFS vs. TTP Definition | Frequency of F/U | | | OR (95% CI) | P value | | | HR (95% CI) | P value
Author, year | Study arm (patient number) | Response criteria | PFS vs. TTP Definition | Frequency of F/U | Mutation+ | Mutation− | OR (95% CI) | P value | Mutation+ | Mutation− | HR (95% CI) | P value
Randomized controlled trials
Bokemeyer, 2009^a^ | FOLFOX-4 + cetuximab | Modified WHO | PFS NR | q 8 wk | 39/52 (75) | 30/61 (49) | 3.1 (1.39–6.92) | 0.009 | 5.5 | 7.7 | 2.23 (1.38–3.62) | 0.0009
Bokemeyer, 2009^a^ | FOLFOX-4 | Modified WHO | PFS NR | q 8 wk | 26/47 (55) | 48/73 (66) | 0.64 (0.30–1.37) | 0.34 | 8.6 | 7.2 | 0.71 (0.44–1.15) | 0.1655
Hecht, 2009 | ChBP cohort | RECIST | PFS Radiologic progression or death | q 12 wk
Hecht, 2009 | Oxaliplatin-based | | | | NR | NR | NR | NR | 10 | 10 | NR | NR
Hecht, 2009 | Irinotecan-based | | | | NR | NR | NR | NR | 8 | 13 | NR | NR
Hecht, 2009 | ChB cohort | RECIST | PFS Radiologic progression or death
Hecht, 2009 | Oxaliplatin-based | | | | NR | NR | NR | NR | 11 | 12 | NR | NR
Hecht, 2009 | Irinotecan-based | | | | NR | NR | NR | NR | 12 | 13 | NR | NR
Tol, 2009 | CBC (1’) | RECIST | PFS Progression or death | q 9 wk | NR | NR | NR | NR | 8.1 | 10.5 | NR | 0.04
Tol, 2009 | CB (1’) | RECIST | PFS Progression or death | q 9 wk | NR | NR | NR | NR | 12.5 | 10.6 | NR | 0.80
Van Cutsem, 2009 | FOLFIRI+cetuximab | Modified WHO | PFS NR | q 8 wk | 58/105 (55) | 76/172 (44) | 2.79 (1.75–4.47) | <0.001 | 7.6 | 9.9 | NR | NR
Van Cutsem, 2009 | FOLFIRI | Modified WHO | PFS NR | q 8 wk | 43/87 (49) | 95/176 (54) | 0.83 (0.50–1.39) | 0.57 | 8.1 | 8.7 | NR | NR
Folprecht, 2010 (Germany + Austria) | FOLFOX + cetuximab | RECIST | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Folprecht, 2010 (Germany + Austria) | FOLFIRI + cetuximab | RECIST | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Single arm studies
Yen, 2009 | Cetuximab | RECIST | PFS Progression or death | NR | NR | NR | NR | NR | NR | NR | 3.95 (2.09–6.71) | <0.0001
Tabernero, 2010 | Cetuximab monotherapy phase | WHO | PFS Radiologically confirmed disease progression | NR | NR | NR | NR | NR | NR | NR | NR | NR
Tabernero, 2010 | Cetuximab + FOLFIRI phase | WHO | PFS Radiologically confirmed disease progression | NR | NR | NR | NR | NR | NR | NR | NR | NR
Tabernero, 2010 | Overall analysis (full follow-up period) | WHO | PFS Radiologically confirmed disease progression | NR | NR | NR | NR | NR | 6 | 9 | 2.13 (NR) | 0.0475
Yen, 2010^b^ | Cetuximab+ chemotherapy | RECIST | PFS Tumor progression of death from any cause | NR | NR | NR | NR | NR | NR | NR | 4.15 (2.66–6.48) | <0.0001

a Nine patients were not assessable for response in this study.

b If the analysis is limited to “activating KRAS mutations” (per study definition), the PFS HR=5.81 (3.50–9.66).

CI, confidence interval; FOLFIRI, irinotecan, fluorouracil, and folinic acid; FOLFOX, oxaliplatin, fluorouracil, and folinic acid; F/U, follow-up; HR, hazard ratio; NR, not reported; OR, odds ratio; PFS, progression-free survival; PS, performance status; RECIST, Response Criteria In Solid Tumors; TTP, time-to-progression; WHO, World Health Organization.

Table 15 KRAS and anti-EGFR antibodies for colorectal cancer: progression (salvage treatment)

Author, year | Study arm (patient number) | Response criteria | PFS vs. TTP Definition | Frequency of F/U | Event/patient, n (%) | | OR (95% CI) | P value | Median Survival Time, mo | | HR (95% CI) | P value
Author, year | Study arm (patient number) | Response criteria | PFS vs. TTP Definition | Frequency of F/U | Mutation+ | Mutation- | OR (95% CI) | P value | Mutation+ | Mutation- | HR (95% CI) | P value
Randomized controlled trials
Amado, 2008 | Panitumumab | RECIST | PFS Progression or death | q 4–8 wk | 76/84 (90) | 115/124 (93) | 0.74 (0.27–2.01) | 0.74 | 7.4 | 12.3 | NR | NR
Amado, 2008 | BSC | RECIST | PFS Progression or death | q 4–8 wk | 95/100 (95) | 114/119 (96) | 0.83 (0.23–2.96) | 0.97 | 7.3 | 7.3 | NR | NR
Karapetis, 2008 | Cetuximab | RECIST | PFS Progression or death | q 8 wk | NR | NR | NR | NR | 1.8 | 3.7 | NR | NR
Karapetis, 2008 | BSC | RECIST | PFS Progression or death | q 8 wk | NR | NR | NR | NR | 1.8 | 1.9 | NR | NR
Single arm studies
Moroni. 2005 | Cetuximab +/− chemotherapy; panitumumab monotherapy | RECIST | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Lievre, 2006 | Cetuximab-based (Any lines of therapy) | RECIST | TTP Progression | NR | 13/13 (100) | 17/17 (100) | NE (NE) | NR | 0 | 4.8 | 4.0 (0.99–16.1) | 0.06^a^
Lievre, 2006 | Cetuximab-based (Salvage only) | RECIST | TTP Progression | NR | 13/13 (100) | 14/14 (100) | NE (NE) | NR | 0 | 4.3 | 2.9 (0.72–11.7) | 0.14^b^
Benvenuti, 2007 | Panitumumab or Cetuximab +/− irinotecan | RECIST | PFS^c^ First documented tumor progression or death | NR | NR | NR | NR | NR | NR | NR | NR | 0.0443^d^
Di Fiore, 2007 | Cetuximab + irinotecan or oxaliplatin | RECIST | TTP Progression or death | NR | NR | NR | NR | NR | 3 | 5.5 | NR | 0.015
Frattini, 2007 | Cetuximab + chemotherapy | RECIST | NR | q 6 wk | NR | NR | NR | NR | NR | NR | NR | NR
Khambata-Ford, 2007 | Cetuximab | WHO | PFS Progression or death | q 9 wk | NR | NR | NR | NR | 2.1 | 2.2 | 1.4 (0.87–2.6) | 0.14
Cappuzzo, 2008 | Cetuximab-based | RECIST | TTP Progression | q 2 mo | NR | NR | NR | NR | 4.4 | 5.4 | NR | 0.2
De Rook, 2008 | Cetuximab +/− irinotecan (113) | RECIST | PFS Progression, death from any cause or censoring | q 6 wk^e^ | NR | NR | NR | NR | 3 | 6 | NR | 0.074
Di Nicolantonio, 2008 | Cetuximab +/− chemotherapy; panitumumab monotherapy | RECIST | PFS Progression or death | q 6–8 wk | NR | NR | NR | NR | NR | NR | NR | 0.0275
Freeman, 2008 | Panitumumab | RECIST or WHO | PFS Progression of death | Q8 or 9 wk | 24/24 (100) | 37/38 (97) | 1.96 (0.08–50.09) | >0.9 | 1.9 | 4.1 | 2.50 (1.43–5.00) | <0.002
Goncalves, 2008 | Cetuximab + chemotherapy; cetuximab | WHO | Progression or death | q 2 mo^f^ | NR | NR | NR | NR | 4.7 | 3.9 | NR | 0.968
Lievre, 2008 | Cetuximab-based (primary data n=88) | RECIST | PFS Progression or death from any causes | NR | NR | NR | NR | NR | 2.3 | 7.2 | NR | 0.0001
Lurje, 2008 | Cetuximab | WHO | PFS Progression or death | q 6 wk | NR | NR | NR | NR | 1.3 | 1.4 | 1.49 (1.01–2.20) wt referent | 0.02
Personeni, 2008 | Cetuxmab +/− irinotecan | RECIST | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Bibeau, 2009 | Cetuximab + irinotecan-based chemotherapy | RECIST | PFS Progression or death from any cause | CT q 2–3 m | NR | NR | NR | NR | 3 | 5.3 | 1.8 (1.1–3.1) [adjusted]^g^ | 0.024 0.021 [adjusted]^h^
Garm Spindler, 2009 | Cetuximab + irinotecan | RECIST | PFS Progression or death | NR | NR | NR | NR | NR | 2.3 | 8.0 | NR | <0.0088
Jacobs, 2009 | Cetuximab +/− chemotherapy^i^ | RECIST | PFS Progression of disease or death from any cause | NR | NR | NR | NR | NR | NR | NR | NR | NR
Laurent-Puig, 2009 | Cetuximab +/− irinotecan-based chemotherapy | RECIST | PFS NR | NR | NR | NR | NR | NR | 3 | 8 | NR | <0.001
Loupakis, 2009 | Cetuximab +/− irinotecan | RECIST | PFS Progression or death from any causes | q 8 wk | NR | NR | NR | NR | 3.1 | 4.2 | 2.2 (1.4–3.7) | 0.003
| Cetuximab-based (Pooled analysis n=113) | RECIST | PFS Progression or death from any causes | NR | NR | NR | NR | NR | 2.1 | 7.4 | NR 3.3 (2.0–5.4), [skin toxicity] | 0.00000014 0.0001
Loupakis, 2009^j^ | Cetuximab + irinotecan | RECIST | PFS Progression or death from any causes | q 8 wk | NR | NR | NR | NR | 3.8 | 5.1 | 2.2 (1.1–9.1) | 0.028
Molinari, 2009 | Cetuximab +/− irinotecan | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Muro, 2009 | Panitumumab | RECIST | PFS Progression or death | q 8 wk | NR | NR | NR | NR | 7.3 | 13.2 | NR | NR
Oden-Gangloff, 2009 | Cetuximab + irinotecan-based chemotherapy | RECIST | TTP Progression or death | “on clinical basis” | NR | NR | NR | NR | 3 | 5 | 2.08 (1.06–4.00) [adjusted]^k^ | 0.034 0.032 [adjusted]^l^
Paule, 2009^m^ | Cetuximab + irinotecan | RECIST | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Perrone, 2009 | Cetuximab + irinotecan | RECIST | PFS Progression or death from any causes | q 9 wk | 10/10 (100) | 22/22 (100) | NE (NE) | NR | 4.5 | 8.5 | 3.0 (1.1–7.9) | 0.03^n^
Prenen, 2009 | Cetuximab +/− irinotecan | RECIST | PFS NR | NR^o^ | NR | NR | NR | NR | 3 | 6 | 1.79 (1.53–2.09)^p^ | Log-rank p-value<0.0001
Sartore-Bianchi, 2009 | Cetuximab +/− chemotherapy; panitumumab monotherapy (109) | RECIST | PFS NR | q 6–8 wk | NR | NR | NR | NR | NR | NR | NR | 0.0815
Sartore-Bianchi, 2009 | Cetuximab +/− irinotecan-based chemotherapy or panitumumab monotherapy | RECIST | PFS NR | q 6–8 wk | NR | NR | NR | NR | NR | NR | 1.65 (1.041 – 2.601) | 0.033
Sohn, 2009 | Cetuximab + irinotecan-based chemotherapy | RECIST | PFS Disease progression or death from any cause | q 6–8 wk | NR | NR | NR | NR | 2 | 6 | 1.7 (0.1–3.1) [adjusted for skin toxicity and number of prior chemotherapy regimens] | 0.005 [logrank] 0.068 [adjusted for skin toxicity and number of prior chemotherapy regimens]
Souglakos, 2009 | Cetuximab + chemotherapy | RECIST | PFS Documented progression or death | NR | NR | NR | NR | NR | 3 | 5 | 1.5 (0.9 – 2.3) | 0.09
Chung, 2010 | Cetuximab | RECIST | “PFS” Measured progression of disease^q^ | NR | NR | NR | NR | NR | NR | NR | 1.45 (0.90–1.99) | 0.18
Graziano, 2010 | Cetuximab + irinotecan | RECIST | PFS Progression or death from any cause | NR | NR | NR | NR | NR | NR | NR | 2.3 (1.46–3.7) [adjusted for sex, age, ECOG performance status, number of metastatic sites, CEA levels] | 0.004 [adjusted for sex, age, ECOG performance status, number of metastatic sites, CEA levels]
Montagut, 2010 | Cetuximab + chemotherapy | RECIST | TTP^r^ Documented tumor progression or death | NR | NR | NR | NR | NR | 8 | 25 | NR | 0.01
Perkins, 2010 | Cetuximab +/− irinotecan-based chemotherapy or panitumumab monotherapy | RECIST | PFS Tumor progression or death from any cause | NR | NR | NR | NR | NR | 4 | 8 | NR | <0.001
Scartozzi, 2010 | Cetuximab +/− irinotecan-based chemotherapy | RECIST | PFS Clinical progression or death from any cause | q 8 wk | NR | NR | NR | NR | 2 | 4 | NR | 0.0001

a Estimated from reported individual patient data with an assumption that all patients progressed.

b Estimated from reported individual patient data with an assumption that all patients progressed.

c The study referred to this end-point both as “PFS” and “TTP”.

d Patients with KRAS mutations had reduced PFS compared to wild-type patients.

e Until week 24, 30 or 36; q 12 weeks thereafter.

f For the first 6 mo and every 3 mo thereafter until disease progression.

g Covariates in the multivariate analyses not reported.

h Covariates in the multivariate analyses not reported.

i Patients were recruited from clinical trials investigating diverse treatment strategies.

j Only codon 61 and 146 were assessed for mutations if patients had no mutations in codon 12 or 13 (n=76).

k Gender, age, previous number of treatment, and TP53 status was used as covariates.

l Gender, age, previous number of treatment, and TP53 status was used as covariates.

m Mortality data at 4 years.

n Estimated from reported individual patient data with an assumption that all patients progressed.

o Patients were participating in clinical trials of cetuximab. Follow-up was “as planned in these trials”.

p Reported hazard ratio was inverted for consistency.

q The definition provided for this outcome is typically described as time-to-progression (TTP).

r Although the study reports “TTP” the definition used is that of PFS.

CEA, carcinoembryonic antigen; CI, confidence interval; FOLFIRI, irinotecan, fluorouracil, and folinic acid; FOLFOX, oxaliplatin, fluorouracil, and folinic acid; F/U, follow-up; HR, hazard ratio; NR, not reported; OR, odds ratio; PFS, progression-free survival; PS, performance status; RECIST, Response Criteria In Solid Tumors; TTP, time-to-progression; WHO, World Health Organization.

#### Response

##### Strength of the association between KRAS testing results and response

Tables 14 and 17 summarize KRAS associations with treatment failure (by radiologic criteria) in the first- and second-line settings, respectively. Overall, failure rates were higher in patients with KRAS mutations rather than wild-type patients. Particularly in studies of patients who had received prior chemotherapy, the response rates in the presence of KRAS mutations were typically very low (often 0, see Table 17).

All of the RCT-based analyses reported response results in antibody-treated and comparator arms, stratified by KRAS mutation status. The 5 RCTs enrolling first-line patients presented lower sensitivity and specificity compared to the 2 RCTs enrolling patients pre-treated with cytotoxic chemotherapy. Four of the 5 RCTs included a non-anti-EGFR antibody arm (in Folprecht 2010 all patients received cetuximab). Among these studies, predictive accuracy was higher in the antibody-treated arms compared to the comparator arms. Only the study by van Cutsem 2009 presented the results of a treatment-by-KRAS mutation interaction test. The test was statistically significant (p=0.03) indicating that the relative response rate of anti- EGFR antibody treated patients compared to those in the comparator arms was different between KRAS mutated and wild-type patients.

Table 16 KRAS and anti-EGFR antibodies for colorectal cancer: treatment failure by radiologic criteria (first line therapy)

Author, year | Study arm (patient number) | Response criteria [RECIST or WHO] | Definition of response [cutoff point and timing] | Patient, n | | | | Sensitivity (95% CI) | Specificity (95% CI) | LR + (95% CI) | LR − (95% CI)
Author, year | Study arm (patient number) | Response criteria [RECIST or WHO] | Definition of response [cutoff point and timing] | | | | | Sensitivity (95% CI) | Specificity (95% CI) | LR + (95% CI) | LR − (95% CI)
Author, year | Study arm (patient number) | Response criteria [RECIST or WHO] | Definition of response [cutoff point and timing] | Mutation + | | Mutation − | | Sensitivity (95% CI) | Specificity (95% CI) | LR + (95% CI) | LR − (95% CI)
Author, year | Study arm (patient number) | Response criteria [RECIST or WHO] | Definition of response [cutoff point and timing] | | | | | Sensitivity (95% CI) | Specificity (95% CI) | LR + (95% CI) | LR − (95% CI)
Author, year | Study arm (patient number) | Response criteria [RECIST or WHO] | Definition of response [cutoff point and timing] | Resp − (TP) | Resp + (FP) | Resp − (FN) | Resp + (TN) | Sensitivity (95% CI) | Specificity (95% CI) | LR + (95% CI) | LR − (95% CI)
Randomized controlled trials
Bokemeyer, 2009^a^ | FOLFOX-4 + cetuximab | Modified WHO | CR+PR | 34 | 17 | 22 | 37 | 0.61 (0.47, 0.74) | 0.69 (0.54, 0.80) | 1.9 | 0.6
Bokemeyer, 2009^a^ | FOLFOX-4 | Modified WHO | CR+PR | 22 | 23 | 42 | 27 | 0.34 (0.23, 0.47) | 0.54 (0.39, 0.68) | 0.8 | 1.2
Hecht, 2009 | ChBP cohort Oxaliplatin-based | RECIST | CR+PR | 72 | 63 | 100 | 101 | 0.42 (0.34, 0.50) | 0.62 (0.54, 0.69) | 1.1 | 0.9
Hecht, 2009 | Irinotecan-based | RECIST | CR+PR | 33 | 14 | 26 | 31 | 0.56 (0.42, 0.69) | 0.69 (0.53, 0.82) | 1.8 | 0.6
Hecht, 2009 | ChB cohort Oxaliplatin-based | RECIST | CR+PR | 70 | 55 | 89 | 114 | 0.44 (0.36, 0.52) | 0.67 (0.60, 0.74) | 1.4 | 0.8
Hecht, 2009 | Irinotecan-based | RECIST | CR+PR | 24 | 15 | 30 | 28 | 0.44 (0.31, 0.59) | 0.65 (0.49, 0.79) | 1.3 | 0.9
Tol, 2009 | CBC (1’) | RECIST | CR+PR | 53 | 45 | 61 | 97 | 0.46 (0.37, 0.56) | 0.68 (0.60, 0.76) | 1.47 | 0.78
Tol, 2009 | CB (1’) | RECIST | CR+PR | 44 | 64 | 78 | 78 | 0.36 (0.28, 0.45) | 0.55 (0.46, 0.63) | 0.8 | 1.16
Van Cutsem, 2009 | FOLFIRI+cetuximab | Modified WHO | CR+PR | 67 | 38 | 70 | 102 | 0.49 (0.40, 0.58) | 0.73 (0.65, 0.80) | 1.8 | 0.7
Van Cutsem, 2009 | FOLFIRI | Modified WHO | CR+PR | 52 | 35 | 100 | 76 | 0.34 (0.27, 0.42) | 0.68 (0.59, 0.77) | 1.1 | 1.0
Folprecht, 2010 | FOLFOX + cetuximab | RECIST | CR+PR | 16 | 11 | 20 | 47 | 0.44 (0.28, 0.62) | 0.81 (0.69, 0.90) | 2.3 | 0.7
Folprecht, 2010 | FOLFIRI + cetuximab | RECIST | CR+PR
Single arm studies
Yen, 2009 | Cetuximab + chemotherapy | RECIST | CR+PR (numbers represent mutation status as defined by primary tumor sample) | 24 | 4 | 7 | 41 | 0.77 (0.59, 0.90) | 0.91 (0.79, 0.98) | 8.71 | 0.25
Tabernero, 2010 | Cetuximab monotherapy phase | WHO | CR+PR | 9 | 0 | 21 | 8 | 0.30 (0.15, 0.49) | 1.00 (0.63, 1.00) | >100 | 0.7
Tabernero, 2010 | Cetuximab + FOLFIRI phase | WHO | CR+PR | 13 | 6 | 13 | 16 | 0.50 (0.30, 0.70) | 0.73 (0.50, 0.89) | 1.83 | 0.69
Tabernero, 2010 | Overall analysis (full follow-up period) | WHO | CR+PR | 13 | 6 | 13 | 16 | 0.50 (0.30, 0.70) | 0.73 (0.50, 0.89) | 1.83 | 0.69
Yen, 2010^b^ | Cetuximab+ chemotherapy | RECIST | CR+PR | 32 | 9 | 8 | 46 | 0.80 (0.64, 0.91) | 0.84 (0.71, 0.92) | 4.89 | 0.24

a Nine patients were not assessable for response in this study.

b If the analysis is limited to “activating KRAS mutations” (per study definition), then TP = 29, FP = 4, FN = 8, TN = 46.

CB, capecitabine, oxaplatin, bevacizumab; CBC, capecitabine, oxaplatin, bevacizumab, cetuximab; ChB, chemotherapy, bevacizumab; ChBP, chemotherapy, bevacizumab, panitumumab;

Table 17 KRAS and anti-EGFR antibodies for colorectal cancer: treatment failure by radiologic criteria (salvage therapy)

Author, year | Study arm (patient number) | Response criteria [RECIST or WHO] | Definition of response [cutoff point and timing] | Patient, n | | | | Sensitivity (95% CI) | Specificity (95% CI) | LR + (95% CI) | LR − (95% CI)
Author, year | Study arm (patient number) | Response criteria [RECIST or WHO] | Definition of response [cutoff point and timing] | | | | | Sensitivity (95% CI) | Specificity (95% CI) | LR + (95% CI) | LR − (95% CI)
Author, year | Study arm (patient number) | Response criteria [RECIST or WHO] | Definition of response [cutoff point and timing] | Mutation + | | Mutation − | | Sensitivity (95% CI) | Specificity (95% CI) | LR + (95% CI) | LR − (95% CI)
Author, year | Study arm (patient number) | Response criteria [RECIST or WHO] | Definition of response [cutoff point and timing] | | | | | Sensitivity (95% CI) | Specificity (95% CI) | LR + (95% CI) | LR − (95% CI)
Author, year | Study arm (patient number) | Response criteria [RECIST or WHO] | Definition of response [cutoff point and timing] | Resp − (TP) | Resp + (FP) | Resp − (FN) | Resp + (TN) | Sensitivity (95% CI) | Specificity (95% CI) | LR + (95% CI) | LR − (95% CI)
Randomized controlled trials
Amado, 2008 | Panitumumab | RECIST | CR+PR | 69 | 0 | 21 | 87 | 0.77 (0.67, 0.85) | 1.00 (0.96, 1.00) | >100 | 0.23
Amado, 2008 | BSC | RECIST | CR+PR | 68 | 0 | 103 | 0 | 0.40 (0.32, 0.48) | NA | NA | NA
Karapetis, 2008 | Cetuximab | RECIST | “Objective response” | 80 | 1 | 102 | 15 | 0.44 (0.37, 0.51) | 0.94 (0.70, 1.00) | 7.03 | 0.6
Karapetis, 2008 | BSC | RECIST | “Objective response” | 83 | 0 | 113 | 0 | 0.42 (0.35, 0.50) | NA | NA | NA
Single arm studies
Moroni, 2005 | Cetuximab +/− chemotherapy; panitumumab monotherapy | RECIST | CR+PR | 8 | 2 | 13 | 8 | 0.38 (0.18, 0.62) | 0.80 (0.44, 0.97) | 1.9 | 0.77
Lievre, 2006 | Cetuximab-based (Any lines of therapy) | RECIST | CR+PR | 13 | 0 | 6 | 11 | 0.68 (0.43, 0.87) | 1.00 (0.72, 1.00) | >100 | 0.32
Lievre, 2006 | Cetuximab-based (Salvage only) | RECIST | CR+PR | 13 | 0 | 6 | 8 | 0.68 (0.43, 0.87) | 1.00 (0.63, 1.00) | >100 | 0.32
Benvenuti, 2007 | Cetuximab +/− irinotecan Panitumumab | RECIST | CR+PR | 15 | 1 | 22 | 10 | 0.41 (0.25, 0.58) | 0.91 (0.59, 1.00) | 4.46 | 0.65
Di Fiore, 2007 | Cetuximab + irinotecan or oxaliplatin | RECIST | CR+PR (DS) | 16 | 0 | 31 | 12 | 0.34 (0.21, 0.49) | 1.00 (0.74, 1.00) | >100 | 0.66
Frattini, 2007 | Cetuximab + chemotherapy | RECIST | CR+PR | 9 | 1 | 8 | 9 | 0.53 (0.28, 0.77) | 0.90 (0.55, 1.00) | 5.29 | 0.52
Khambata-Ford, 2007 | Cetuximab | WHO | CR+PR+SD | 27 | 3 | 26 | 24 | 0.51 (0.37, 0.65) | 0.89 (0.71, 0.98) | 4.58 | 0.55
Cappuzzo, 2008 | Cetuximab-based | RECIST | NR (“based-on RECIST”) | 38 | 4 | 28 | 10 | 0.58 (0.45, 0.70) | 0.71 (0.42, 0.92) | 2.02 | 0.59
De Rook, 2008 | Cetuximab +/− irinotecan | RECIST | CR+PR | 32 | 0 | 26 | 22 | 0.55 (0.42, 0.68) | 1.00 (0.85, 1.00) | >100 | 0.45
Di Nicolantonio, 2008 | Cetuximab +/− chemotherapy; panitumumab monotherapy | RECIST | CR+PR | 32 | 2 | 57 | 22 | 0.36 (0.26, 0.47) | 0.92 (0.73, 0.99) | 4.31 | 0.7
Freeman, 2008 | Panitumumab | RECIST or WHO (pooled analysis) | CR + PR | 24 | 0 | 34 | 4 | 0.41 (0.29, 0.55) | 1.00 (0.40, 1.00) | >100 | 0.59
Freeman, 2008 | Panitumumab | RECIST or WHO (pooled analysis) | CR+PR (DS+ SnaPshot assay + PCR-LCR) | 22 | 0 | 25 | 12 | 0.47 (0.32, 0.62) | 1.00 (0.74, 1.00) | >100 | 0.53
Freeman, 2008 | Panitumumab | RECIST or WHO (pooled analysis) | CR+PR+SD | 13 | 3 | 15 | 28 | 0.46 (0.28, 0.66) | 0.90 (0.74, 0.98) | 4.8 | 0.59
Freeman, 2008 | Panitumumab | RECIST or WHO (pooled analysis) | CR+PR+SD (DS+ SnaPshot assay + PCR-LCR) | 17 | 5 | 11 | 26 | 0.61 (0.41, 0.78) | 0.84 (0.66, 0.95) | 3.76 | 0.47
Goncalves, 2008 | Cetuximab + chemotherapy; cetuximab | WHO | CR+PR | 12 | 2 | 7 | 11 | 0.63 (0.38, 0.84) | 0.85 (0.55, 0.98) | 4.11 | 0.44
Lievre, 2008 | Cetuximab-based (primary data n=89) | RECIST | CR+PR | 24 | 0 | 39 | 26 | 0.38 (0.26, 0.51) | 1.00 (0.87, 1.00) | >100 | 0.62
Lievre, 2008 | Cetuximab-based (Pooled analysis n=114) | RECIST | CR+PR | 36 | 0 | 44 | 34 | 0.45 (0.34, 0.57) | 1.00 (0.90, 1.00) | >100 | 0.55
Lurje, 2008 | Cetuximab | WHO | CR+PR | 37 | 0 | 65 | 12 | 0.36 (0.27, 0.46) | 1.00 (0.74, 1.00) | >100 | 0.64
Personeni, 2008 | Cetuximab +/− irinotecan | RECIST | CR + PR | 29 | 0 | 33 | 28 | 0.47 (0.34, 0.60) | 1.00 (0.86, 1.00) | >100 | 0.53
Bibeau, 2009 | Cetuximab + irinotecan-based chemotherapy | RECIST | CR+PR | 26 | 1 | 27 | 10 | 0.49 (0.35, 0.63) | 0.91 (0.59, 1.00) | 5.4 | 0.56
Garm Spindler, 2009 | Cetuximab + irinotecan | RECIST | CR+PR | 22 | 0 | 25 | 17 | 0.47 (0.32, 0.62) | 1.00 (0.80, 1.00) | >100 | 0.53
Jacobs, 2009 | Cetuximab +/− chemotherapy^a^ | RECIST | CR+PR | 86 | 1 | 67 | 52 | 0.32 (0.14, 0.55) | 1.00 (0.69, 1.00) | >100 | 0.68
Laurent-Puig, 2009 | Cetuximab +/− irinotecan-based chemotherapy | RECIST | CR+PR | 52 | 1 | 64 | 52 | 0.63 (0.38, 0.84) | 0.85 (0.55, 0.98) | 4.11 | 0.44
Loupakis, 2009 | Cetuximab +/− irinotecan | RECIST | CR+PR+SD6 (Primary tumors only [n=88]) | 33 | 2 | 40 | 13 | 0.45 (0.34, 0.57) | 0.87 (0.60, 0.98) | 3.39 | 0.63
Loupakis, 2009 | Cetuximab +/− irinotecan | RECIST | CR+PR+SD6 (Metastatic tumors only [n=48]) | 19 | 2 | 16 | 11 | 0.54 (0.37, 0.71) | 0.85 (0.55, 0.98) | 3.53 | 0.54
Loupakis, 2009 | Cetuximab + irinotecan | RECIST | CR+PR (codon 12, 13, 61, 146 in all patients [n=138]) | 56 | 3 | 57 | 24 | 0.50 (0.40, 0.59) | 0.89 (0.71, 0.98) | 4.46 | 0.57
Loupakis, 2009 | Cetuximab + irinotecan | RECIST | CR+PR (codon 12, 13 only in all patients [n=138]) | 48 | 3 | 63 | 24 | 0.43 (0.34, 0.53) | 0.89 (0.71, 0.98) | 3.89 | 0.64
Loupakis, 2009 | Cetuximab + irinotecan | RECIST | CR+PR (codon 61, 146 only in patients free from mutations in 12 or 13 [n=76]) | 8 | 0 | 46 | 22 | 0.15 (0.07, 0.27) | 1.00 (0.85, 1.00) | >100 | 0.85
Molinari, 2009 | Cetuximab +/− irinotecan | RECIST | CR+PR | 5 | 0 | 5 | 2 | 0.50 (0.19, 0.81) | 1.00 (0.16, 1.00) | >100 | 0.5
Muro, 2009 | Panitumumab | RECIST | CR+PR | 10 | 0 | 10 | 4 | 0.50 (0.27, 0.73) | 1.00 (0.40, 1.00) | >100 | 0.5
Oden-Gangloff, 2009 | Cetuximab + irinotecan-based chemotherapy | RECIST | CR+PR | 18 | 0 | 30 | 16 | 0.38 (0.24, 0.53) | 1.00 (0.79, 1.00) | >100 | 0.62
Paule, 2009^b^ | Cetuximab + irinotecan | RECIST | CR+PR | 2 | 0 | 10 | 7 | 0.38 (0.18, 0.62) | 0.80 (0.44, 0.97) | 1.9 | 0.77
Perrone, 2009 | Cetuximab + irinotecan | RECIST | CR+PR | 7 | 0 | 15 | 10 | 0.32 (0.14, 0.55) | 1.00 (0.69, 1.00) | >100 | 0.68
Prenen, 2009 | Cetuximab +/− irinotecan | RECIST | CR+PR | 76 | 1 | 85 | 37 | 0.47 (0.39, 0.55) | 0.97 (0.86, 1.00) | 17.94 | 0.54
Sartore-Bianchi, 2009 | Cetuximab +/− irinotecan-based chemotherapy or panitumumab monotherapy | RECIST | CR+PR | 33 | 2 | 72 | 24 | 0.68 (0.43, 0.87) | 1.00 (0.72, 1.00) | >100 | 0.32
Sartore-Bianchi, 2009 | Cetuximab +/− chemotherapy; panitumumab monotherapy | RECIST | CR+PR | 30 | 2 | 57 | 20 | 0.34 (0.25, 0.45) | 0.91 (0.71, 0.99) | 3.79 | 0.72
Sohn, 2009 | Cetuximab + irinotecan-based chemotherapy | RECIST | CR+PR | 26 | 1 | 26 | 13 | 0.68 (0.43, 0.87) | 1.00 (0.63, 1.00) | >100 | 0.32
Souglakos, 2009 | Cetuximab + chemotherapy | RECIST | CR+PR | 32 | 0 | 46 | 14 | 0.53 (0.28, 0.77) | 0.90 (0.55, 1.00) | 5.29 | 0.52
Chung, 2010 | Cetuximab | RECIST | NR | NR | NR | NR | NR | NR | NR | NR | NR
Graziano, 2010 | Cetuximab + irinotecan | RECIST | CR+PR | 55 | 3 | 40 | 23 | 0.58 (0.47, 0.68) | 0.88 (0.70, 0.98) | 5.02 | 0.48
Perkins, 2010 | Cetuximab +/− irinotecan-based chemotherapy or panitumumab monotherapy | RECIST | CR+PR | 19 | 0 | 11 | 12 | 0.63 (0.44, 0.80) | 1.00 (0.74, 1.00) | >100 | 0.37
Montagut, 2010 | Cetuximab + chemotherapy | RECIST | CR+PR | 12 | 0 | 25 | 11 | 0.32 (0.18, 0.50) | 1.00 (0.72, 1.00) | >100 | 0.68
Scartozzi, 2010 | Cetuximab +/− irinotecan-based chemotherapy | RECIST | CR+PR | 43 | 0 | 45 | 24 | 0.49 (0.38, 0.60) | 1.00 (0.86, 1.00) | >100 | 0.51

a Patients were recruited from clinical trials investigating diverse treatment strategies.

b Mortality data at 4 years.

BSC, best supportive care; CB, capecitabine, oxaplatin, bevacizumab; CBC, capecitabine, oxaplatin, bevacizumab, cetuximab; CR, complete response; FN, false negative; FP, false positive; PR, partial response; Resp, response (defined as complete and partial remission); SD, stable disease; SD6, stable disease lasting >6 mo; TN, true negative; TP, true positive.

##### Meta-analysis: KRAS for predicting anti-EGFR antibody failure by radiological imaging

For the meta-analysis, we focused on 24 studies that appeared to have nonoverlapping populations (Figure 5) and were conducted in the metastatic setting. These studies reported on a total of 2938 patients of whom 1121 had KRAS mutations in codons 12 or 13. In the studies by Tol 2009 and Hecht 2009, anti-EGFR antibodies were administered with bevacizumab, an anti-VEGF antibody, and cytotoxic chemotherapy. Because these were the only studies that combined two targeted agents we only included them in sensitivity analysis. Finally, 22 studies^a^ were included in the main meta-analysis.(58;59;61;68;74–78;81;86;88;94–102;106)

a From 42 papers.

To assess whether specific factors may influence the ability of KRAS mutations to predict response to anti-EGFR antibodies, we performed the following subgroup analyses: percentage of patients who had not been exposed to prior chemotherapy (>80 percent unexposed versus >80 percent in second-line or higher), use of the anti-EGFR antibodies in combination with chemotherapy or as monotherapy (>80 percent monotherapy versus >80 percent in combination therapy), specific antibody used (>80 percent cetuximab versus >80 percent panitumumab). For each subgroup, bivariate meta-analysis of sensitivity and specificity was performed when more than 4 studies were available.

In the main analysis, the presence of KRAS mutations had a summary sensitivity of 0.49 (95% CI: 0.43, 0.55) and a summary specificity of 0.93 (95% CI: 0.87–0.97), corresponding to positive and negative likelihood ratios of 7.3 and 0.5, respectively. Figure 6 presents the results of the meta-analysis in the receiver operating characteristic (ROC) space.

In subgroup analysis, KRAS testing had high summary specificity (higher than 0.90 in all subgroups except in the first-line setting) whereas the summary specificity was low (ranging from 0.47 to 0.57 in the evaluated subgroups). The results of the bivariate meta-analysis of sensitivity and specificity are presented in Table 18.

Figure 6 KRAS and anti-EGFR antibodies for colorectal cancer: meta-analysis of treatment failure by imaging (sensitivity and specificity)

Meta-analysis for the ability of KRAS mutations to predict response to anti-EGFR antibodies. Each study is represented by a gray circle with size proportional to the study size. The summary point is represented by a black square and the dashed line represents the 95% confidence region of the summary estimate.

Figure 6. KRAS and anti-EGFR antibodies for colorectal cancer: meta-analysis of treatment failure by by imaging (sensitivity and specificity). (page 72) Meta-analysis for the ability of KRAS mutations to predict response to anti-EGFR antibodies. Each study is represented by a gray circle with size proportional to the study size. The summary point is represented by a black square and the dashed line represents the 95% confidence region of the summary estimate.

Table 18 KRAS and anti-EGFR antibodies for colorectal cancer: meta-analysis results for treatment failure by imaging (sensitivity, specificity and likelihood ratios)

| Number of studies (KRAS positive/ total) | Sensitivity (95% CI) | Specificity (95% CI) | LR+ | LR−
Main analysis | 22 (841, 2242) | 0.49 (0.43, 0.55) | 0.93 (0.87, 0.97) | 7.3 | 0.5
Including combined antibody therapy (Tol 2009 and Hecht 2009) | 24 (1121, 2938) | 0.49 (0.44, 0.54) | 0.92 (0.85, 0.96) | 5.9 | 0.6
Combination with chemotherapy
>80% monotherapy | 6 (256, 621) | 0.54 (0.43, 0.64) | 0.95 (0.76, 0.99) | 11 | 0.5
>80% combination therapy | 16 (585, 1621) | 0.47 (0.41, 0.53) | 0.92 (0.85, 0.96) | 6.2 | 0.6
Prior chemotherapy
>80% second-line or higher | 17 (598, 1618) | 0.47 (0.41, 0.53) | 0.96 (0.91, 0.98) | 12.3 | 0.6
>80% first-line | 5 (243, 624) | 0.57 (0.46, 0.68) | 0.76 (0.70, 0.81) | 2.4 | 0.6
EGFR antibody
Cetuximab | 19 (738, 1979) | 0.48 (0.42, 0.53) | 0.91 (0.85, 0.95) | 5.5 | 0.6
Panitumumab | 3 (103, 263) | NA | NA | NA | NA

Results of subgroup analysis for the ability of KRAS mutations to predict response to anti-EGFR antibodies. Sensitivities and specificities are presented with their corresponding 95% CI. Positive and negative LRs were calculated form the summary sensitivity and specificity. LR = likelihood ratio.

We also assessed the strength of association between KRAS mutations and response to treatment with anti-EGFR antibodies by performing meta-analysis of predictive odds ratios. Overall, there was a significant association between the presence of KRAS mutations and failure anti-EGFR antibody treatment according to imaging criteria. Based on the main analysis of 22 independent studies (i.e., excluding studies with potential overlap, the 2 neoadjuvant studies and the studies by Tol 2009 and Hecht 2009 which evaluated a combination of two targeted agents), the summary odds ratio was 7.84 (95% CI: 4.86–12.67); p<0.001. Figure 7 presents the forest plot for the results of the main analysis. The association between KRAS mutations and response to EGFR was robust in subgroup analyses. Table 19 presents results from subgroup analyses although the predictive effect was much higher in the second-line or higher treatment setting.

Table 19 KRAS and anti-EGFR antibodies for colorectal cancer: meta-analysis results for treatment failure by imaging (odds ratio)

| Number of studies (KRAS positive/total) | Heterogeneity p-value; I^2^ | Summary odds ratio (95% CI); p-value
Main analysis | 22 (841, 2242) | 0.002; 52% | 7.84 (4.86–12.67); <0.001
Including combined antibody therapy (Tol 2009 and Hecht 2009) | 24 (1121, 2938) | <0.001; 70% | 6.34 (3.96–10.15); <0.001
Combination with chemotherapy
>80% monotherapy | 6 (256, 621) | 0.06; 53% | 11.42 (3.42–38.12); <0.001
>80% combination | 16 (585, 1621) | 0.08; 52% | 7.09 (4.20–11.98); <0.001
Prior chemotherapy
>80% second-line or higher | 17 (598, 1618) | 0.28; 15% | 10.99 (6.48–18.64); <0.001
>80% first line | 5 (243, 624) | 0.01; 68% | 4.16 (2.13–8.12); <0.001
EGFR antibody
Cetuximab | 19 (738, 1979) | 0.02; 46% | 6.74 (4.30–10.56); <0.001
Panitumumab | 3 (103, 263) | 0.06; 65% | 33.25 (1.86–594.88); 0.02

Results of subgroup analysis for the ability of KRAS mutations to predict response to anti-EGFR antibodies. Odds ratios are presented with their corresponding 95% CI. Heterogeneity was quantified with the Q and I^2^ statistics.

Figure 7 KRAS and anti-EGFR antibodies for colorectal cancer: meta-analysis of treatment failure by imaging (odds ratio)

Forest plot of studies evaluating the association between KRAS mutations and anti-EGFR antibody failure by imaging. The point estimate of the odds ratio of each study is represented by a gray square. The size of the square is proportional to the weight of each study in the meta-analysis. Horizontal lines represent the accompanying 95% confidence interval. A diamond stands for the summary estimate of the OR. The width of the diamond represents the confidence interval around the summary estimate. Studies are ordered by year of publication and then by author name.

Figure 7. "KRAS and anti-EGFR antibodies for colorectal cancer: meta-analysis of treatment failure by imaging (odds ratio). (page 74) Forest plot of studies evaluating the association between KRAS mutations and anti-EGFR antibody failure by imaging. The point estimate of the odds ratio of each study is represented by a gray square. The size of the square is proportional to the weight of each study in the meta-analysis. Horizontal lines represent the accompanying 95% confidence interval. A diamond stands for the summary estimate of the OR. The width of the diamond represents the confidence interval around the summary estimate. The overall estimate was statisically significant, indicating the presence of an association between KRAS mutations and treatment failure. The majority of study specific point estimates lay on the right of the null line (where OR=1), indicating that the effect of KRAS mutations was fairly consistent in direction. Confidence intervals for individual estimates were wide."

#### Studies in the neoadjuvant setting

Two small (40 and 41 enrolled patients) studies evaluated KRAS mutations as predictive factors for response to neoadjuvant therapy for patients with rectal cancer.(65;70) Both studies evaluated combinations of cytotoxic agents with cetuximab and radiotherapy.

The first study was a prospective phase II study from Italy (n=39 samples from patients included in the response analysis from a total of 40 enrolled - one patient refused surgery and was not assessable for response).(65) The study treatment consisted of neoadjuvant cetuximab and 5-fluorouracil, concurrently with radiotherapy. KRAS mutations were assessed before study treatment and response was assessed using the Dworak(109) assessment scale, in samples obtained by surgery. KRAS mutations were identified in 9 patients (23 percent) and were not associated with pathologic response to chemoradiotherapy (tumor grade regression 3–4 was observed in 1/9 patients with KRAS mutations versus 11/30 patients with wild-type tumors, p=0.119). Disease-free survival or overall survival analyses were not reported.

The second study was a prospective, phase I/II study from France (n=39 samples from a total of 41 patients enrolled) reported on the ability of KRAS mutations to predict pathologic response and disease-free survival in the neoadjuvant setting.(70) The study treatment consisted of neoadjuvant capecitabine in combination with cetuximab and radiotherapy and at the time of reporting had a median follow-up of 32 months (range: 4.8–46.2). KRAS mutations were assessed before study treatment and response was assessed using the Dworak(109) and Wheeler(110) assessment scales, independently by two pathologists, in samples obtained by surgery. KRAS mutations were identified in 12 patients (31 percent) and were not associated with pathologic response to chemoradiotherapy (details not reported). Per study report, KRAS positive tumors “tended to show regression” using the Wheeler scale (p=0.09) but not using the Dworak scale (p=0.36). In addition, KRAS mutations showed no correlation with tumor downstaging (p=0.69). Disease-free survival results were not presented by KRAS status.

### Key Question 2 What patient- and disease-related factors affect the test results, their interpretation or their predictive response to therapy?

None of the included studies performed analyses for interaction between the aforementioned factors and KRAS mutations to predict response to therapy.

### Key Question 3 How does the gene testing impact the therapeutic choice?

No study explicitly reported details on changes in treatment plans before and after testing. However, KRAS testing is already used to guide treatment in several clinical settings, and thus by definition affects treatment choice in these settings. The absence of the information requested by Key Question 3 is essentially an issue of reporting.

### Key Question 4 What are the benefits and harms or adverse effects for patients when managed with gene testing?

No study explicitly reported evidence on benefits or harms beyond what is covered in Key Question 1

## 2.4 Discussion

Our systematic review of studies on the ability of KRAS mutation testing to predict response to treatment with the anti-EGFR antibodies cetuximab and panitumumab identified consistent evidence that KRAS testing can predict response to treatment in colorectal cancer patients. For all outcomes assessed, patients with KRAS mutations were less likely to experience benefit with anti-EGFR antibody treatment, compared to patients whose tumors were wild-type for KRAS mutations. The direction of the association is consistent for overall mortality, disease progression and treatment failure by radiologic imaging. In three out of four RCT-based analyses of progression free survival, the treatment-by-KRAS mutation interaction was significant and in the anticipated direction. In brief, a substantial body of evidence suggests that testing somatic KRAS mutations predicts differential response to anti-EGRF therapy in colorectal cancer patients.

Most individual studies reporting overall and disease-free survival reached formal statistical significance. Most studies pertained to patients who had received previous cytotoxic chemotherapy. Our conclusions are analogous to a recently published provisional clinical opinion by the American Society of Clinical Oncology,(111) the recent changes implemented by the Food and Drug Administration (FDA) on the product labels of both cetuximab and panitumumab^a^, and similar decisions by the European Medicines Agency (EMeA).^b^ Further, our results are in agreement with a previous systematic review that included a smaller number of studies of patients who were pre-treated with cytotoxic chemotherapy and only assessed treatment failure as an outcome.(112)

a http://www.fda.gov/AboutFDA/CentersOffices/CDER/ucm172905.htm; last accessed on December 7^th^, 2009.

b http://www.emea.europa.eu/humandocs/PDFs/EPAR/erbitux/089404en8.pdf; last accessed on December 7^th^, 2009.

In seven studies in the first line setting the ability of KRAS mutations to predict adverse outcomes seemed to be lower compared to studies in pre-treated patients.(58;61;91) This was true for all outcomes and particularly for treatment failure by radiologic imaging. For example, the positive likelihood ratio for “ruling in” treatment failure under anti-EGFR antibody treatment based on the summary sensitivity and specificity was 12.3 for studies in the second-line or higher setting compared to 2.4 for studies in the first-line setting. A postulated explanation is that, in the salvage setting, many patients are resistant to cytotoxic chemotherapy, and most of their benefit comes from the anti-EGFR treatment. Therefore, in pretreated patients (salvage setting) the modifying effect of KRAS mutations on the anti-EGFR therapy is not diluted by the effect of cytotoxic chemotherapy, and is more readily observable. For these reasons, we argue that there is need for further research especially in the first line setting.(113) Ideally this can be studied in future RCTs of anti-EGFR agents by prespecifying analyses by KRAS status, or by “repurposing” already completed RCTs in which anti-EGFR antibodies were used as first line treatments. In the latter case, one would perform genetic analyses in archival tissue from RCT enrollees, and associate them with the prospectively recorded clinical outcomes.

The benefits of implementing KRAS mutation testing to guide treatment for colorectal cancer have been evaluated in a prospective cost-effectiveness analysis based on the National Cancer Institute of Canada Clinical Trials Group CO.17 (which was included in the present systematic review(77)^c^). The cost-effectiveness analysis concluded that implementing pharmacogenetic testing for KRAS mutations improves the incremental cost-effectiveness ratio of cetuximab over best supportive care (in the particular study setting), and that “from a health-care system perspective, it would not be efficient to fund cetuximab treatment for all patients with advanced colorectal cancer”.(114)

c see Karapetis, 2008(77), a retrospective analysis of a phase III RCT comparing cetuximab plus best supportive care versus best supportive care for patients with chemotherapy pre-treated colorectal cancer.

Regarding the two different agents, cetuximab and panitumumab, the predictive ability of KRAS mutations appears to be similar, although the bulk of available evidence for this subgroup comparison was related to studies assessing panitumumab as monotherapy, and in all cases in patients pre-treated with cytotoxic chemotherapy. It should be noted that panitumumab is currently approved by the FDA only for use as a single agent for patients “with disease progression on or following fluoropyrimidine, oxaliplatin, and irinotecan chemotherapy regimens”.^d^

d http://www.accessdata.fda.gov/drugsatfda_docs/label/2009/125147s080lbl.pdf; last accessed on December 7^th^, 2009.

In conclusion, this review identified a substantial body of evidence consisting of small retrospective analyses and analyses based on RCTs, assessing KRAS mutations as a pharmacogenetic test for predicting response to anti-EGFR antibodies.