# Section 1: Variations in CYP2D6 and response to tamoxifen in breast cancer

## 1.1 Background

Endocrine therapies targeting estrogen action are the mainstay of treatment for breast cancers expressing estrogen or progesterone receptors (ER/PR), which constitute more than 80 percent of all breast cancers. In fact, endocrine therapies for ER/PR expressing breast cancer are considered as some of the most successful forms of “targeted therapy”, since women whose tumors do not express the ER/PR receptors are not expected to derive benefit from endocrine treatments.(11) Currently, the two main forms of endocrine treatments for breast cancer are selective estrogen receptor modulators (SERMs) and aromatase inhibitors.(12)

SERMs act by selectively behaving as antagonists (inhibitors) or agonists of the ER in different tissues. Tamoxifen and its metabolites exert their activity by binding to the ER and blocking the binding of estrogen (competitive inhibition) in breast tissue, while acting as ER agonists in bone and endometrial tissue. This prevents the activation of ER-mediated signaling and suppresses ER-dependent tumor cell proliferation. Aromatase inhibitors block the conversion of adrenal androgens to estrogen by aromatase, an enzyme expressed in peripheral tissues. Peripheral aromatization is the main source of estrogen in women for whom the ovaries are no longer a source of estrogen due to ovarian ablation or, most commonly menopause. The focus of this review is tamoxifen resistance, and aromatase inhibitors will not be considered further.

Based on extensive randomized clinical trial evidence, tamoxifen is considered the standard of care for premenopausal women with ER/PR positive breast cancer, as well as a valid option for the treatment of post-menopausal women. Although an individual-patient data meta-analysis of 194 randomized controlled trials (145,000 patients) has demonstrated that tamoxifen reduces the risk of breast cancer relapse by about 50 percent and the risk of breast-cancer specific mortality by about 30 percent, a substantial number of women with ER-positive breast cancer develop disease relapse following surgical resection despite tamoxifen use.(11) In addition, response to tamoxifen in the metastatic setting is usually short lived and disease progression is inevitable. Tamoxifen resistance has been extensively investigated and a variety of biological mechanisms are considered as potentially mediating treatment resistance, including cross talk of the ER/PR-activated pathway and growth-factor signaling pathways, activation of alternative (non-ER-dependent) signaling pathways, loss of ER expression and ER mutations (a rare cause of resistance).(13–15)

Inherited polymorphisms that influence tamoxifen metabolism are increasingly recognized as a source of between-individual variation in treatment response.(16) Cytochrome P450 (CYP) enzymes play a major role in the metabolism of tamoxifen and its conversion to active metabolites. Tamoxifen is converted into N-desmethylatamoxifen and 4-hydroxytamoxifen, by the cytochrome 450 (CYP) enzymes CYP3A4/5 and CYP2D6, respectively.(17) These metabolites in turn undergo oxidation and are converted into endoxifen (4-hydroxy-N-desmethyltamoxifen), which is the pharmacologically active metabolite of tamoxifen. Based on the higher blood concentration, binding affinities and in vitro potency of tamoxifen metabolites compared to tamoxifen, it appears that these metabolites are the primary effectors of tamoxifen activity.(18;19)

To date, more than 75 CYP2D6 variants have been recognized.(20)^a^ The majority of those variants appear to be functionally silent, do not influence enzymatic activity, and are commonly referred to as “extensive metabolizer” (EM) alleles. Other variants of the CYP2D6 gene result in the absence of enzymatic activity (“null” variants) and are referred to as “slow metabolizer” (SM) alleles. A third group of variants have intermediate enzymatic activity and are called “intermediate metabolizer” (IM) alleles.(16;20) Duplication or multiplication of normal and null activity alleles has been reported, resulting in “ultra rapid metabolizer” (UM) and slow metabolizer phenotypes, respectively.(21;22)

a A comprehensive list is available at: http://www.cypalleles.ki.se/cyp2d6.htm (last accessed April, 22nd, 20100).

Because intermediate and slow metabolizer genotypes are associated with reduced enzymatic activity, patients who carry these genotypes may have impaired conversion of tamoxifen to its active metabolites, endoxifen and N-desmethylatamoxifen.(23) Indeed, both in vitro and in vivo studies have demonstrated that SM and IM genotypes are associated with lower levels of tamoxifen metabolite concentrations compared to EM genotypes, although a substantial portion of the variability in metabolite concentrations is not explained by CYP2D6 genotype. In addition, drugs that inhibit CYP2D6 (such as selective-serotonin reuptake inhibitors (SSRIs)^b^, haloperidol and amiodarone) have also been shown to reduce tamoxifen metabolite concentrations, both in animal models and in humans. The potential association of SSRI use and reduced tamoxifen levels (and activity) is of particular relevance in breast cancer therapeutics, because SSRIs are often coprescribed with tamoxifen to alleviate hot flashes (a common tamoxifen side effect).

b Fluoxetine (Prozac), paroxetine (Paxil), bupropion (Wellbutrin), and duloxetine (Cymbalta) can substantially inhibit CYP2D6 activity. Citalopram (Celexa), escitalopram (Lexapro), desvenlafaxine (Pristiq), and sertraline (Zoloft) are weaker inhibitors. Venlafaxine (Effexor) appears to have no effect on CYP2D6 activity.

Based on these observations, it has been hypothesized that breast cancer patients with slow (and intermediate) metabolizer genotypes who are treated with tamoxifen may have worse clinical outcomes compared to patients with extensive metabolizer genotypes.(23)

## 1.2 Methods

The reader is referred to the Generic Methods Section for a description of methods common to all three topics examined in this review. Herein we describe the topic-specific Key Questions, as well as additional topic-specific methods.

### Key Questions

1. Does CYP2D6 testing predict response to tamoxifen therapy?
2. What patient- and disease-relevant factors affect the test results, their interpretation or their predictive response to therapy?
3. How does the gene testing impact the therapeutic choice?
4. What are the benefits and harms or adverse effects for patients when managed with gene testing?

The reader is referred to the Generic Methods section in the beginning of this Technology Assessment for a description of the Key Questions.

### Eligibility criteria

Eligible were studies that fulfilled the generic eligibility criteria listed in the Generic Methods section. Briefly, eligible studies reported on women with breast cancer and presented information on clinical outcomes (mortality and/or overall survival; disease recurrence or progression free survival or time-to-progression or response rates) stratified by CYP2D6 polymorphism status. We considered all study designs (prospective and retrospective), tamoxifen doses, and dosing schedules.

### Extracted data

See the Generic Methods Section for commonly extracted items across the three cancer topics. Data specifically collected for studies pertinent to the current topic include the percentage of postmenopausal women, details of treatment setting (metastatic versus nonmetastatic disease, stage distribution, proportion with lymph node involvement, proportion with positive estrogen and progesterone receptor status, proportion positive for HER2, tamoxifen doses, potential cotreatments, information on comedications that inhibit CYP2D6 enzymatic activity, and adherence to tamoxifen schedule.

### Deducing metabolizer status from CYP2D6 genotypes

To demonstrate the heterogeneity in the definition of CYP2D6-derived genotypes in the included studies we used a simple, if arbitrary, algorithm to group genotypes in the slow, intermediate, and extensive metabolizer categories. We classified genotypes with two, one, or none of the “slow” (impaired) CYP2D6 alleles as slow, intermediate and extensive metabolizers, respectively. Allele classification was based on a curated CYP allele classification database.^a^

a http://www.cypalleles.ki.se/cyp2d6.htm; last accessed December 7^th^, 2009.

### Outcomes

For studies evaluating tamoxifen in the adjuvant setting, clinical outcomes of interest were mortality (survival), recurrence (as defined in each study), and the composite outcome of death or recurrence.

For studies in the metastatic setting, clinical outcomes of interest were mortality (survival), disease progression (as defined in each study) or the composite outcome of death or progression.

### Synthesis

We did not perform quantitative synthesis (meta-analysis) because of extensive heterogeneity in the definition of slow, intermediate and extreme metabolizers across eligible studies (see 1.3 Results). Instead, we present results from individual studies on the strength of the associations between CYP2D6 testing results and clinical outcomes. We list odds ratios and 95 percent confidence intervals (for analyses of cumulated events) or hazard ratios and 95 percent confidence intervals (for time-to-event analyses).

## 1.3 Results

### Literature flow

Our searches returned 590 citations. After screening of titles and abstracts 51 were retrieved and reviewed in full text. Sixteen publications were finally accepted (Figure 2).(15;24–38) Appendices B and C show the list of included and excluded citations, respectively.

Figure 2 CYP2D6 and tamoxifen for breast cancer: literature flow

* “Irrelevant” includes publications with no primary data, studies on healthy population, and studies on medications that inhibit CYP2D6.

Figure 2. CYP2D6 and tamoxifen for breast cancer: literature flow. (page 13) Figure 2 is a type of diagram that depicts the literature search, and literature scan. The electronic literature search (MEDLINE) yielded 588 citations, of which 51 papers were retrieved in full text. 12 and 1 were considered for reviews of postsurgical adjuvant therapy for stage I-III resectable disease and adjucant for stage IV (so called metastatic) disease, respectively, of which 13 were included. 38 were excluded for the following reasons: No CYP2D testing performed (n=11), no clinical outcomes of interest reported (n=6), or irrelevant (n=21). Irrelevant category includes publications with no primary data, studies on healthy population, and studies on medications that inhibit CYP2D6.

### Characteristics of included studies

Table 1 summarizes the characteristics of the 16 eligible studies.(15;24–38)

#### Patients

Briefly, all but one(27) studies pertained to women who received adjuvant tamoxifen for nonmetastatic breast cancer. Mean or median participant age was 65 or older in 7 out of 13 studies that reported this information. As shown in Table 1, the distribution of breast cancer stages varied across studies. Similarly, the proportion of women with positive lymph node status, positive estrogen or progesterone receptor status was quite heterogeneous across studies. In terms of racial composition, 9 studies pertained to White populations, 6 studies pertained to East Asian populations, and one study enrolled predominantly African-American women.

#### Treatments

Tamoxifen dosing was not reported in the majority of studies.

#### Design

Ten studies were retrospective.(26;28–32;34;35) In the remaining five(15;24;25;27;33), outcome assessment was described as prospective and one study combined a prospective and a retrospective cohort.(38) The majority of studies (n=9) assessed the ability of CYP2D6 testing to predict outcomes only in women who received tamoxifen.(15;24;26–28;30;31;34;35) This design essentially assumes that CYP2D6 testing has no predictive ability for breast cancer outcomes in patients who did not receive tamoxifen.^a^ Two studies were “repurposed” RCTs, i.e., RCTs that were reanalyzed to examine the ability of CYP2D6 status to predict outcomes.(25;33) The “repurposed” RCTs analyzed women who received tamoxifen (one arm), as well as women who received other treatments (comparator arm), and have the opportunity to examine pharmacogenetic effects of CYP2D6 genotyping by testing the interaction of genotypes and treatments.^b^ However, as will be discussed later, none of the repurposed RCTs performed interaction tests. Effectively they were analyzed in the same way as the aforementioned 12 studies.

a If CYP2D6 status predicted, e.g. breast cancer outcome irrespective of treatment, studies that evaluate only tamoxifen treated women would still find an association between CYP2D6 status and patient outcomes; however the association would not be specific to tamoxifen treated people, and therefore would not be evidence for a pharmacogenetic interaction.

b Testing for interaction answers whether an observed association between CYP2D6 status and patient outcomes is specific to those who received tamoxifen, or is independent of treatment. This analysis would not invoke the assumption outlined in the previous footnote.

Sample sizes in the 16 studies ranged between 21 and 1361. Median followup duration ranged from 20 to 150 months, and was longer than 56 months in 13 studies. There was extensive overlap in the patient populations included in the following studies: Goetz 2005(25), Goetz 2008(15), Scroth 2007(32) and Scroth 2009(38). In addition, there was complete overlap of the patient populations in Kiyotani 2008(26) and Kiyotani 2010(37).

Table 1 CYP2D6 and tamoxifen for breast cancer: characteristics of included studies

Author, year Ethnicity (Country) | Sample size, n Study design Sampling | Selection criteria | Median age, y [range] (% post- menopause) | -Treatment setting -Stage distribution, n (%) -LN involvement, n (%) | ER/PR+, % [method] HER2+, % [method] | Follow-up in months Median [range] | -CYP2D6 inhibitors -TAM adherence
Prospective – adjuvant setting
Goetz, 2005(25) White 92% (USA) | Total 256 Post-hoc analysis of a multicenter RCT^a^ Convenience sampling | Postmenopausal with node-negative disease (T1c or T2N0M0) ≥65 years with node-positive disease (T1NxM0 or T2N1M0) | 68 [42–83] (100) | -Adjuvant -Tumor >30 mm, 54 (21) -96 (38) | -ER+: 100 -HER2+: NR | 137 [68–169]^b^ | NR
Wegman, 2005(33) NR (Sweden) | TAM 112; No TAM 114^c^ Post-hoc analysis of a multicenter 2×2 RCT Convenience sampling | Postmenopausal women age <70 y Unilateral operable breast cancer Histologically verified lymph node metastasis or a tumor >30 mm Fresh-frozen tissue available | <70 y [NR] (100) | -Adjuvant -Tumor >30 mm, 25 (11); Node+, tumor ≤20 mm, 89 (39); Node+, tumor >20 mm, 112 (50) -201 (89) | -ER+: 69 [NR] -HER2+: NR | 128 [2–223] | NR
Goetz, 2008(15) NR (USA) | Total 110 Post-hoc analysis of RCT Convenience sampling | Postmenopausal women with resected, node-negative, ER+ breast cancer | 65 [42–84] (100) | -Adjuvant -Tumor size ≥3 cm, 22 (20) -0 | -ER +: 100 [IHC or quantitative] PR +: NR -HER2 +: 19 [3+ IHC] | 150 [68–186]^a^ | -CYP2D6 inhibitors groups with slow metabolizers. -NR
Bijl, 2009(24) NR (Netherlands) | TAM 85 Post-hoc analysis of TAM-treated women from a prospective population-based cohort study^d^ | Women started on TAM between 1991 and 2005, with follow-up >=180 days and available genotype. | 76 [NR] NR | NR | NR | NR | -Analyses adjusted for CYP2D6 inhibitors -NR
Retrospective – adjuvant setting
Wegman, 2007(34) Whites (Sweden) | TAM 677 Retrospective cohort study^e^ Convenience sampling | Postmenopausal patients with stage II/III breast cancer from the South East Health Care Region of Sweden (1986–1997) | 69 [50–96]^f^ (100) | -Adjuvant -II, 581 (86); III, 96 (14) -171(28) | -ER+: 100 [NR] -HER2+: NR | 85 [0.5–215] | NR
Schroth, 2007(32) Whites (Germany) | TAM 206; 280 chemotherapy or no therapy^g^ Retrospective non-RCS Convenience sampling | Primary invasive breast cancer, diagnosed between 1986 and 2000 Follow-up ≥ 8 months and tissue for genotyping available | TAM-treated: 68 [40–92] No-TAM: 56 [29–88] (NR) | -Adjuvant -NR -TAM: 57 (31) No TAM: 118 (44) | All TAM-treated where -ER+ [NR] -HER2+: NR | 71 [4–227] | -Not accounted for in the analysis due to incomplete data -NR
Nowell, 2005(29) Whites 81%; African- American 19% (USA) | TAM 165; No TAM 172 Single center Retrospective non-RCS Convenience sampling | Primary invasive breast cancer “Registered” on hospital tumor registry Received any type of adjuvant therapy as part of first-line therapy No prior history of cancer | 41% <50 y, 59% >50 y (NR) | -Adjuvant -I, 106 (31); II node-, 71 (21); II node+, 95 (28); III, 49 (15); IV, 16, (5) -(see above) | NR | ~62^h^ [NR] | NR
Xu, 2008(35) East Asian (China) | TAM 152; chemotherapy 141 Single-center retrospective non-RCS Convenience sampling | Primary breast cancer with adjuvant TAM, no concurrent chemo DNA from samples available | NR^i^ | -Adjuvant -TAM: 0, 8 (5); I, 104 (68); II, 40 (26); No TAM: I, 24 (17); II, 91 (65); III, 22 (16) -TAM: 10 (7) No TAM 59 (42) | ER+: TAM-treated: 125 (82); No TAM: 24 (16) [IHC or dextran coated charcoal method] PR+: TAM-treated: 95 (67); No TAM: 51 (36) [IHC or dextran coated charcoal method] HER2+: TAM-treated: 21 (14); No TAM: NR [IHC] | TAM 63 [4–122]; No TAM 120 [4–193] | -None of the eligible subjects in the TAM group were on CYP2D6 inhibitors
Kiyotani, 2008(26) East Asian (Japan) | TAM 67 Retrospective cohort “Consecutive” patients | Inflammatory breast cancer, adjuvant TAM, ER + tumor. | 50 [34–82] (48) | -Adjuvant -NR | ER+: (96) [IHC] PR+: (90) [IHC] HER2+: (5) [IHC] | 96 [19–259] | -None of patients received SSRIs. -NR
Newman, 2008(28) Whites (United Kingdom) | TAM 115 (47 BRCA1, 68 BRCA2) Retrospective cohort study Convenience sampling | Probands from breast cancer families from a single cancer genetics center, BRCA1 or BRCA2 positive, received TAM following surgery | BRCA1: 41 [26–68] BRCA2: 44 [27–68] (NR) | -Adjuvant -NR -BRCA1: 22 (47); BRCA2: 25 (37) | BRCA1: ER+, 58 [NR] BRCA2: ER+, 91 [NR] HER2 +: NR | 120 [NR]^j^ | -4 patients concomitantly taking SSRIs were included.
Okishiro, 2009(30) East Asian (Japan) | TAM 173 (+/− chemotherapy) Retrospective cohort study Convenience sampling^k^ | Primary, ER+ breast cancer, received adjuvant TAM (with or without chemotherapy) | 47 [22–73] (22) | -Adjuvant -NR -50 (29) | ER+: 91 [IHC] PR+: 86 [IHC] HER2 +: 8 [FISH or IHC] | 56 [8–109] | -Patients receiving paroxetine concomitantly with TAM excluded -NR
Ramón y Cajal, 2009(31) Whites (Spain) | TAM 91 (+/− chemotherapy) Retrospective single-center cohort study Convenience sampling | Patients evaluated at the study center in 2007 Receiving TAM (monotherapy or concomitantly with chemotherapy) Radiotherapy and/or chemotherapy-treated patients were included | 51 [28–79] (40) | -Adjuvant -I, 30 (33); II, 39 (43); III, 22 (24) -45 (50) | -ER+: 100 [NR] -HER2+: NR | 108 [91–133]^l^ | -Not accounted for in the analysis due to incomplete data -NR
Schroth, 2009(38) NR (Germany, USA) | TAM 1361 (1325 included in analyses) Combined analysis of a retrospective cohort study and a post-hoc analysis of a multicenter RCT Convenience sampling (“consecutive” patients from the German cohort) | Histologically confirmed breast cancer patients recommended to receive 5 years of adjuvant TAM therapy ER/PR + tumors | 66 [37–93] (96) | -Adjuvant -I-III (distribution NR) -449 (34) | ER+: (97) [IHC] PR+: (74) [IHC] HER2+: NR | 76 [2–244] | -Not accounted for in the analysis due to incomplete data -Not accounted for in the analysis due to “insufficient control”
Toyama, 2009(36) East Asian (Japan) | TAM 156 Retrospective single-center cohort study Convenience sampling (“consecutive” patients) | Primary node-negative invasive breast cancer Patients planned to receive 2–5 years of adjuvant tamoxifen | 59.1 [33–89] (NR) | -Adjuvant -NR -0 | ER+: (96) [IHC] PR+: (80) [IHC] HER2+: (6) [IHC] | 95 [25–249] | -NR
Kiyotani, 2010(37) East Asian (Japan) | TAM 282 Retrospective multicenter cohort study Convenience sampling | Primary breast cancer patients with localized hormone-receptor positive disease Scheduled to receive 5 years of TAM | 51 [31–83] (53%) | -Adjuvant -NR -48 (17%) | ER+: (74) [IHC] PR+: (69) [IHC] HER2+: (2) [IHC] | 85 (10–282) | -NR
Prospective – metastatic setting
Lim HS, 2007(27) East Asian (Korea) | TAM 21 Single center prospective cohort study | Histologically/ cytologically confirmed ER+ or PR+ breast cancer | 46.5 [31–70] (NR) | -Metastatic -Stage IV, 11 (52), Recurrent disease, 10 (48) -NR | ER+: 100 [IHC] HER2: 10 [IHC or FISH] | 20 [7–54] | -Patients receiving CYP2D6 inhibitors or inducers within 28 days of study enrollment were excluded -NR

a NCCTG 89-30-52.

b Alive patients only.

c 226 out of 679 postmenopausal women from 960 trial participants (i.e., 24% of total trial participants)

d The Rotterdam Study a prospective cohort study that included 7983 women from the general population aged >55 years

e 235 patients had participated in an RCT of 2 vs. 5 years TAM.

f Mean [range].

g An additional 135 patients who received chemotherapy + TAM or had unclear estrogen receptor status were excluded.

h Approximated from reported person-years.

i Age reported as >50 or <50 years only.

j Patients were followed-up for a median 10 years or until death.

k Study reports “serial” sampling of patients.

l Mean age [range].

Studies are grouped according to whether outcomes were ascertained prospectively or retrospectively in the adjuvant or metastatic setting. Within each group studies are ordered by decreasing sample size.

ER, estrogen receptor; FISH, fluorescence in situ hybridization; IHC, immunohistochemistry; LN, lymph node; Non-RCS, non-randomized comparative study; NR, not reported; PR, progesterone receptor; RCT, randomized clinical trial; TAM, tamoxifen.

### Heterogeneity in the classification of genotypes to categories of enzymatic activity

Patients can be classified as slow, intermediate or extensive metabolizers of tamoxifen according to the activity of the CYP2D6 enzyme. Genotypic testing of CYP2D6 is a surrogate of the actual enzymatic activity of the CYP2D6 protein in a given patient. However, different studies classified the same genotypes into different categories of (predicted) enzymatic activity.

Table 2 provides details on which genotypes were considered as slow, intermediate or extensive metabolizers by each study. Figure 3 summarizes the information in Table 2. It is evident that there is considerable heterogeneity in the definition of metabolizer status across studies. This heterogeneity should be kept in mind when comparing the results of individual studies between them, and is the main reason why a meta-analysis was not performed in this topic.

Figure 3 CYP2D6 and tamoxifen for breast cancer: heterogeneity in the definition of slow, intermediate and extensive metabolizers across studies

We grouped genotypes into extensive, intermediate and slow metabolizers (EM, IM and SM, respectively) following the conventions outlined in Section 1.2. The big boxes correspond to the three metabolizer groups. Filled cells imply that a genotype has been assessed in a given study. The color of the cells corresponds to each study’s definitions of metabolizer status (EM = dark gray; IM = medium gray; SM = light gray).

Genotypes *1/*1 and wt/wt (which we considered as EM) were consistently considered as EM by all studies. On the contrary, the genotypes that we defined as IM were variably treated as EM, IM or SM by different studies (all three colors appear in the “IM” box). Similarly, genotypes that we defined as SM were treated both as SM and IM by the studies. Genotypes *4/*4, *4/*5 and *5/*5 were consistently treated as SM by all studies that investigated them. Studies are presented in the same order as in Table 1. Not all genotypes reported in the study by Ramon y Cajal 2009 are depicted in the table (see Table 2 for the exact classification in that study).

Figure 3. CYP2D6 and tamoxifen for breast cancer: heterogeneity in the definition of slow, intermediate and extensive metabolizers across studies. (page 18) We grouped genotypes into extensive, intermediate and slow metabolizers (EM, IM and SM, respectively) following the conventions outlined in Section 1.2. Three big boxes correspond to the three metabolizer groups, as defned by our arbitrary classification system. Filled cells imply that a genotype has been assessed in a given study. The color of the cells corresponds to each study’s definitions of metabolizer status (EM = dark gray; IM = medium gray; SM = light gray). The heterogeneity in genotype groupings and polymorphisms evaluated in each study is highlighted in this figure. For example, genotypes *1/*1 and wt/wt (which we considered as EM) were consistently considered as EM by all studies. On the contrary, the genotypes that we defined as IM were variably treated as EM, IM or SM by different studies (all three colors appear in the “IM” box). Similarly, genotypes that we defined as SM were treated both as SM and IM by the studies. Genotypes *4/*4, *4/*5 and *5/*5 were consistently treated as SM by all studies that investigated them. Studies are presented in the same order as in Table CYP2D6_CHARACTERISTICS. Not all genotypes reported in the study by Ramon y Cajal 2009 are depicted in the table (see Table CYP2D6_GENOTYPES for the exact classification in that study).

Several observations can be made in Figure 3. Allowing for the caveats mentioned in the “1.2 Methods” section, ideally all green cells would fall into the EM box, all blue cells would fall into the IM box, and all red cells in the SM box. By definition, some empty cells in this figure (corresponding to alleles that were not assessed) fall into the “wild type” category. For example, Goetz 2005 did not assess for the *5 allele. Therefore, e.g. the *5/*5 genotype is implicitly in the “wild type” wt/wt category (i.e., would be green in the figure). Further, some studies, (e.g., Ramon y Cajal 2009), classified genotypes in a complex and not adequately supported way (Table 2).

Table 2 CYP2D6 and tamoxifen for breast cancer: genotype detection methods, metabolic phenotype definitions and frequency of genotypes in eligible studies

Study (first author, year) | Genotyping method | Source of DNA for genotyping | Available sample, n Genotyping success, n (%) | Genotypes | | Frequency, n (%)
Prospective outcome assessment – adjuvant setting
Goetz, 2005 | TaqMan® Allelic Discriminatory Assay | Tissue with high tumor in PET (n=213) or fresh buccal mucosal tissue (n=10) | 190 (85)^a^ | SM | *4/*4 | 13 (7)
Goetz, 2005 | TaqMan® Allelic Discriminatory Assay | Tissue with high tumor in PET (n=213) or fresh buccal mucosal tissue (n=10) | 190 (85)^a^ | IM | - | -
Goetz, 2005 | TaqMan® Allelic Discriminatory Assay | Tissue with high tumor in PET (n=213) or fresh buccal mucosal tissue (n=10) | 190 (85)^a^ | EM | *4/wt wt/wt | 40 (21) 137 (72)
Wegman, 2005 | PCR-RFLP^b^ | Fresh-frozen tumor tissue | 226 (100) | SM | *4/*4 *4/*1 | 9 (4) 55 (24)
Wegman, 2005 | PCR-RFLP^b^ | Fresh-frozen tumor tissue | 226 (100) | IM | - | -
Wegman, 2005 | PCR-RFLP^b^ | Fresh-frozen tumor tissue | 226 (100) | EM | *1/*1 | 162 (72)
Goetz, 2008 | TaqMan® Allelic Discriminatory Assay | Tissue with high tumor in PET or fresh buccal mucosal tissue | 110 (100)^c^ | SM | *4/*4, *4/wt, or on CYP2D6 inhibitor | 32 (29)
Goetz, 2008 | TaqMan® Allelic Discriminatory Assay | Tissue with high tumor in PET or fresh buccal mucosal tissue | 110 (100)^c^ | IM | - | -
Goetz, 2008 | TaqMan® Allelic Discriminatory Assay | Tissue with high tumor in PET or fresh buccal mucosal tissue | 110 (100)^c^ | EM | wt/wt | 78 (71)
Bijl, 2009 | TaqMan® Allelic Discriminatory Assay | Whole blood^d^ | 85 (79) | SM | *4/*4 | 4 (5)
Bijl, 2009 | TaqMan® Allelic Discriminatory Assay | Whole blood^d^ | 85 (79) | IM | *4/*1 | 29 (34)
Bijl, 2009 | TaqMan® Allelic Discriminatory Assay | Whole blood^d^ | 85 (79) | EM | *1/*1 | 52 (61)
Retrospective outcome assessment –adjuvant setting
Nowell, 2005^e^ | TaqMan® Allelic Discriminatory Assay | Normal LN (or other normal tissue) in PET | 337 (100) | SM | *4/*4 *4/wt | 8 (2) 97 (28)
Nowell, 2005^e^ | TaqMan® Allelic Discriminatory Assay | Normal LN (or other normal tissue) in PET | 337 (100) | IM | - | -
Nowell, 2005^e^ | TaqMan® Allelic Discriminatory Assay | Normal LN (or other normal tissue) in PET | 337 (100) | EM | wt/wt | 240 (71)
Schroth, 2007 | MALDI-TOF MS and TaqMan® real-time quantification assays^f^ | Normal breast tissue from PET | TAM-treated: 206 (197 genotyped, 95.6%) No-TAM: NR | SM | Two null alleles (*4/*5) | 14 (7)
Schroth, 2007 | MALDI-TOF MS and TaqMan® real-time quantification assays^f^ | Normal breast tissue from PET | TAM-treated: 206 (197 genotyped, 95.6%) No-TAM: NR | IM | Two *10/*41 or one null allele (*4/*5) together with one *10/*41 allele | 16 (8)
Schroth, 2007 | MALDI-TOF MS and TaqMan® real-time quantification assays^f^ | Normal breast tissue from PET | TAM-treated: 206 (197 genotyped, 95.6%) No-TAM: NR | EM | Homozygous EM (no *4/*5 alleles and not more than one *10/*41 allele) Heterozygous EM (one null allele (*4/*5) and no *10/*41 allele) | 18 (60)
Wegman, 2007 | PCR RFLP | Microdissected frozen breast tumor tissue | 677 (100) | SM | *4/*4 | 35 (5)
Wegman, 2007 | PCR RFLP | Microdissected frozen breast tumor tissue | 677 (100) | IM | *4/*1 | 186 (27)
Wegman, 2007 | PCR RFLP | Microdissected frozen breast tumor tissue | 677 (100) | EM | *1/*1 | 475 (70)
Xu, 2008 | PCR RFLP | Blood or tumor (fresh-frozen), or tumor-free lymph nodes (PET) | 152 (100)^g^ | SM | *10/*10 | 72 (48)
Xu, 2008 | PCR RFLP | Blood or tumor (fresh-frozen), or tumor-free lymph nodes (PET) | 152 (100)^g^ | IM | - | -
Xu, 2008 | PCR RFLP | Blood or tumor (fresh-frozen), or tumor-free lymph nodes (PET) | 152 (100)^g^ | EM | *10/wt or wt/wt | 80 (52)
Kiyotani, 2008 | Multiplex PCR-based Invader assay and Taqman assay | Blood | 67 (100)^h^ | SM | *10/*10 | 15 (22)
Kiyotani, 2008 | Multiplex PCR-based Invader assay and Taqman assay | Blood | 67 (100)^h^ | IM | *1/*10 | 23 (34)
Kiyotani, 2008 | Multiplex PCR-based Invader assay and Taqman assay | Blood | 67 (100)^h^ | EM | *1/*1 | 20 (30)
Newman, 2008 | TaqMan® Allelic Discriminatory Assay | Peripheral blood lymphocytes | 115 (100) | SM | *3,*4, or *5/*3, *4, or *5^i^ | 8 (7)
Newman, 2008 | TaqMan® Allelic Discriminatory Assay | Peripheral blood lymphocytes | 115 (100) | IM | - | -
Newman, 2008 | TaqMan® Allelic Discriminatory Assay | Peripheral blood lymphocytes | 115 (100) | EM | wt/*3,*4, or *5 wt/wt | 40 (35) 67 (58)
Okishiro, 2009 | TaqMan® Allelic Discriminatory Assay | Peripheral blood mononuclear cells | 173 (100) | SM | *10/*10 | 40 (23)
Okishiro, 2009 | TaqMan® Allelic Discriminatory Assay | Peripheral blood mononuclear cells | 173 (100) | IM | - | -
Okishiro, 2009 | TaqMan® Allelic Discriminatory Assay | Peripheral blood mononuclear cells | 173 (100) | EM | wt/wt, *10/wt | 132 (77)
Ramón y Cajal, 2009 | Microarray hybridization method (AmpliChip CYP450 GeneChip®) | Whole blood | 91 (100) | SM | *4/*4 *3/*4 *4/*41 *4/*9 | 5 (6) 1 (1) 2 (2 2 (2)
Ramón y Cajal, 2009 | Microarray hybridization method (AmpliChip CYP450 GeneChip®) | Whole blood | 91 (100) | IM | *9/*10 *9/*41 *41/*41 *1/*4 *1/*5 *1/*6 *2/*4 *2/*5 *2/*20 *35/*4 *1/*10 *1/*9 *1/*41 *35/*10 *2/*9 *2/*41 *35/*41 *35/*9 | 4 (4) 1 (1) 1 (1) 9 (10) 7(8) 1 (1) 2 (2) 2 (2) 1 (1) 1 (1) 3 (3) 3 (3) 7 (7) 1 (1) 2 (2) 3 (3) 1 (1) 1 (1)
Ramón y Cajal, 2009 | Microarray hybridization method (AmpliChip CYP450 GeneChip®) | Whole blood | 91 (100) | EM | *1/*1 *1/*2 *1/*35 *2/*2 *2/*35 *1×N/*2 *3×N/*41 | 11 (12) 10 (11) 3 (3) 4 (4) 1 (1) 1 (1) 1 (1)
Schroth, 2009 | German cohort: MALDI-TOF MS and TaqMan® real-time quantification assays^j^ USA cohort: TaqMan® Allelic Discriminatory Assay | Blood (601 samples) Tumor (fresh-frozen, 101 samples; PET, 659 samples) | 1325 (97) | SM | *3/*3 *3/*4 *3/*5 *4/*4 *4/*5 *5/*5 | 79 (46)
Schroth, 2009 | German cohort: MALDI-TOF MS and TaqMan® real-time quantification assays^j^ USA cohort: TaqMan® Allelic Discriminatory Assay | Blood (601 samples) Tumor (fresh-frozen, 101 samples; PET, 659 samples) | 1325 (97) | IM | wt/*3 wt/*4 wt/*5 wt/*10 wt/*41 *1/*3 *1/*4 *1/*5 *1/*10 *1/*41 2×*2/*3 2×*2/*4 2×*2/*5 2×*2/*10 2×*2/*41 | 637 (48)
Schroth, 2009 | German cohort: MALDI-TOF MS and TaqMan® real-time quantification assays^j^ USA cohort: TaqMan® Allelic Discriminatory Assay | Blood (601 samples) Tumor (fresh-frozen, 101 samples; PET, 659 samples) | 1325 (97) | EM | wt/wt wt/*1 *1/*1 wt/2×*2 *1/2×*2 2×*2/2×*2 | 609 (6)
Toyama, 2009 | TaqMan® Allelic Discriminatory Assay | Tumor (fresh-frozen)^k^ | 154 (99) | SM | *10/*10 | 28 (18)
Toyama, 2009 | TaqMan® Allelic Discriminatory Assay | Tumor (fresh-frozen)^k^ | 154 (99) | IM | wt/*10 | 62 (40)
Toyama, 2009 | TaqMan® Allelic Discriminatory Assay | Tumor (fresh-frozen)^k^ | 154 (99) | EM | wt/wt | 64 (42)
Kiyotani, 2010 | Taqman assay and multiplex PCR-based Invader assay | | | SM | *5/*5 *5/*10 *5/*21 *5/*41 *10/*10 *10/*10-*10 *10/*21 *10/*36-*36 *10/*41 | 63 (22)
Kiyotani, 2010 | Taqman assay and multiplex PCR-based Invader assay | | | IM | *1/*4 *1/*5 *1/*10 *1/*10-*10 *1/*14 *1/*21 *1/*36-*36 *1/*41 *1-*1/*10 | 136 (48)
Kiyotani, 2010 | Taqman assay and multiplex PCR-based Invader assay | | | EM | *1/*1 | 83 (29)
Prospective outcome assessment –metastatic setting
Lim HS, 2007 | Long PCR and PCR-RFLP | Peripheral blood leucocytes | 21 (NR) | SM | *10/*10 | 12 (57)
Lim HS, 2007 | Long PCR and PCR-RFLP | Peripheral blood leucocytes | 21 (NR) | IM | - | -
Lim HS, 2007 | Long PCR and PCR-RFLP | Peripheral blood leucocytes | 21 (NR) | EM | wt/wt, wt/*10 | 9 (43)

^a b c^

^b c^

^c^

d Based on Bijl MJ, et al. Br J Clin Pharmacol, 2008. 65 (4):558.

e Although CYP2D6*3 and *6 were also examined, individuals with these allele(s) were not analyzed separately from “wild type” due to low frequency.

f CYP2D6*10 was not in Hardy Weinberg equilibrium, but the meaning of this departure is unclear.

^g^

h Other genotypes [CYP2D6

i For analyses of recurrence and recurrence free survival, patients on CYP2D6 inhibitors were also included.

j CYP2D6*10 was not in Hardy Weinberg equilibrium.

k Results were compared with DNA extracted from blood for 50 patients (100% concordance).

EM, extensive metabolizer; HWE, Hardy-Weinberg equilibrium; IM, intermediate metabolizer; MALDI-TOF MS, matrix-assisted, laser desorption/ioanization, time-of-flight mass spectrometry; PCR, polymerase chain reaction; PET, Paraffin embedded tissue; RFLP, restriction fragment length polymorphism; SM, slow metabolizers.

### Key Question 1 Does CYP2D6 testing predict response to tamoxifen therapy?

Fifteen studies evaluated the association of CYP2D6 testing results with clinical outcomes in the adjuvant setting.(15;24–26;28–35) Their results are summarized below.

#### Studies in the adjuvant setting – mortality

##### Strength of the association between CYP2D6 testing results and mortality

Table 3 summarizes odds ratios (from analyses of cumulated deaths) and hazard ratios (from time-to-death analyses) for slow or intermediate metabolizers compared to extensive metabolizers.

Only seven studies reported analyses on overall survival (mortality) outcomes.(24;28;29;32) None demonstrated a statistically significant relationship between CYP2D6-defined metabolizer status and overall survival or mortality in either adjusted or unadjusted analyses. The point estimates in five of seven studies suggested a trend towards increased mortality with slow compared to extensive metabolizers among tamoxifen-treated women, but the corresponding confidence intervals were wide.

It is interesting to note that two of the seven studies were nonrandomized studies informing on clinical outcomes in tamoxifen-treated versus non tamoxifen-treated women.^a^(29;32) However, neither of the two performed interaction tests to evaluate whether the strength of the association between CYP2D6-defined metabolizer status and mortality differs by treatment type. If anything, in the Nowell 2005 study the hazard ratios for mortality in the two tamoxifen treated strata are very similar, suggesting that a formal interaction test would be statistically nonsignificant. In the other study (Schroth 2007) such a comparison cannot be made (no effect sizes are reported among women who were not treated with tamoxifen).

a The study by Scroth 2009 only reported on the tamoxifen-treated arm of patients participating in the US North Central Cancer Treatment Group (NCCTG) 89-30-52 trial and thus is not counted among the “repurposed RCT” group of studies.

Many of the studies presented regression-adjusted estimates of the effect of CYP2D6 genotype on mortality risk, frequently for factors that could not conound the genotype-response association.

Table 3 CYP2D6 and tamoxifen for breast cancer: mortality (adjuvant setting)

Author, year | Study arm (patient number) | Mortality Event/patient, n (%) | | | OR (95% CI) | Overall survival times (median survival time in years) | | | Crude HR (95% CI) Adjusted HR (95% CI), [covariates]
| | SM | IM | EM | | SM | IM | EM
Goetz, 2005 | TAM (190) | NR | - | NR | NR | NR | - | NR | SM vs EM 1.73 (0.79–3.76) 1.12 (0.50–2.50), [S]
Nowell, 2005 | TAM (162) | 7/48 (15) | - | 27/114 (24) | SM vs EM 0.51 (0.19–1.43) | 0.028^a^ | - | 0.046^n^ | SM vs EM 0.77 (0.32–1.81), [A, S, ER, PR]
| No TAM (175) | 18/49 (37) | - | 48/126 (38) | SM vs EM 0.94 (0.45–1.96) | 0.063^n^ | - | 0.080^n^ | SM vs EM 0.79 (0.42–1.26), [A, S, ER, PR]
Schroth, 2007 | TAM (197) | NR | NR | NR | NR | NR | NR | NR | SM+IM vs EM 1.73 (0.88–3.41)
| No-TAM (NR) | NR | NR | NR | NR | NR | NR | NR | NR
Newman, 2008 | TAM (115) | NR | NR | NR | NR | NR | NR | NR | SM vs EM+IM 3.5 (0.8–15.4)^b^
Bijl, 2009^c^ | TAM (85) | 4/4 (100) | 19/29 (66) | 30/52 (58) | 1.69 (0.67–4.23) | NR | NR | NR | IM vs EM 1.5 (0.8–2.8) SM vs EM 1.9 (0.6–5.6)
Schroth, 2009 | TAM (1325) | 18/79 (23) | 114/637 (18) | 102/609 (17) | NR | NR | NR | NR | SM+IM vs EM 1.15 (0.88–1.51), [S]^d^
Toyama, 2009 | TAM (154) | NR | NR | NR | NR | NR | NR | NR | “p=NS” by log-rank test

a Deaths/person-year.

b This study also defined a group of patients with “overall reduced CYP2D6 activity”, defined as SM genotype or use of a CYP2D6 inhibitor. Comparing this group with all other patients, the HR for OS=2.5 (0.8–8.2), adjusted for LN status

c This study reports mortality from a population-based cohort of breast cancer patients. No information is provided for the stage at diagnosis or line of treatment of eligible patients. We abstracted mortality data for “incident TAM users”.

d Analyses were stratified by menopausal status, and subcohort assignment (prospective versus retrospective).

Adjusted effects shown in bold font. Covariate key: A, Age; S, Severity; ER, Estrogen receptor status; PR, Progesterone receptor status.

#### Studies in the adjuvant setting – recurrence

##### Strength of the association between CYP2D6 testing results and recurrence

Table 4 summarizes odds ratios (from analyses of cumulated events) and hazard ratios (from time-to-event analyses) for slow or intermediate metabolizers compared to extensive metabolizers.

Fourteen studies reported time-to-tumor recurrence outcomes. Most studies did not report statistically significant relationships between CYP2D6-derived metabolizer status and recurrence or time-to-recurrence. Six studies reported significant associations between slower (slow or intermediate) versus extensive metabolizer status and increased odds for recurrence or shorter time to recurrence for at least one analysis. Again, studies that had information for women treated with tamoxifen and women not treated with tamoxifen did not analyze metabolizer status by treatment interactions.

Many of the studies presented regression-adjusted estimates of the effect of CYP2D6 genotype on disease recurrence risk, frequently for factors that did not satisfy the causal structure of a confounder of the genotype-response association.

Table 4 CYP2D6 and tamoxifen for breast cancer: recurrence (adjuvant setting)

Study (first author, year) | Study arm | Recurrence or mortality Events/patient, n (%) | | | OR (95% CI) | Recurrence free survival times (median survival time in years) | | | Crude HR (95% CI) Adjusted HR (95% CI), [covariates]
| Study arm | | | | OR (95% CI) | | | | Crude HR (95% CI) Adjusted HR (95% CI), [covariates]
| Study arm | SM | IM | EM | OR (95% CI) | SM | IM | EM | Crude HR (95% CI) Adjusted HR (95% CI), [covariates]
Goetz, 2005 | TAM (190) | NR | - | NR | NR | NR | - | NR | SM vs EM^a^ 2.44 (1.22–4.90) 1.86 (0.91–3.82), [S]
Nowell, 2005 | TAM (162) | 10/48 (21) | - | 38/112 (34) | SM vs EM 0.51 (0.21–1.19) | 0.019^b^ | - | 0.073^q^ | SM vs EM 0.67 (0.33–1.35), [A, S, ER, PR]
Nowell, 2005 | No TAM (175) | 18/46 (39) | - | 53/120 (44) | SM vs EM 0.81 (0.38–1.71) | 0.075^q^ | - | 0.110^q^ | SM vs EM 0.69 (0.40–1.18), [A, S, ER, PR]
Wegman, 2005 | TAM (79) | 6/24 (25) | - | 25/52 (48) | SM vs EM^c^ 0.36 (0.10–1.16) | NR | - | NR | NR
Wegman, 2005 | No TAM (78) | 15/23 (65) | - | 27/55 (49) | SM vs EM^d^ 1.94 (0.64–6.17) | NR | - | NR | NR
Wegman, 2007 | TAM (677) | 2/35 (6) | 42/186 (23) | 103/475 (22) | SM+IM vs EM 0.90 (0.60–1.33) | NR | NR | NR | NR
Schroth, 2007 | TAM (197) | 5/14 (36) | 5/16 (31) | Homozygous EM 17/118 (14) Heterozygous EM 14/49 (29) | SM+IM vs (homozygous) EM 2.97 (1.18–7.43) | NR | NR | NR | SM+IM vs (homozygous) EM 1.89 (1.10–3.25)
Schroth, 2007 | No TAM (NR) | NR | NR | NR | NR | NR | NR | NR | “Differences were not observed in the control group”
Goetz, 2008^e^ | TAM (110) | 67/78 | NR | 24/32 | SM vs EM 2.03 (0.62–6.30)^f^ | NR | NR | NR | NR
Kiyotani, 2008 | TAM-treated (67) | 7/15 | 4/23 | 1/20 | SM vs EM 16.6 (1.8–158.1) IM vs EM 4.0 (0.4–39.2) SM vs IM+EM 6.7 (1.7–26.4)^g^ | NR | - | NR | NR
Newman, 2008 | TAM (115) | NR | NR | NR | NR | NR | NR | NR | SM vs EM 2.9 (0.9–9.4)^h,i^
Xu, 2008 | TAM (152) | NR | NR | NR | NR | NR | - | NR | SM vs EM 4.7 (1.1–20.0), [A, S, ER, PR, T]
Xu, 2008 | No TAM (141) | NR | NR | NR | NR | NR | - | NR | NR
Okishiro, 2009 | TAM (173) | NR | - | NR | NR | 63 | - | 54 | SM vs IM+EM 0.94 (0.34–2.60) 0.60 (0.18–1.92), [S, PR, T]
Ramón y Cajal, 2009 | TAM (91) | NR | NR | NR | NR | 8.2 | 9.5 | 9.8 | NR^j^
Schroth, 2009 | TAM (1325) | 26/79 (33) | 176/637 (28) | 135/609 (22) | NR | NR | NR | NR | SM+IM vs EM 1.33 (1.06–1.68), [S]^k^
Toyama, 2009 | TAM (154) | NR | NR | NR | NR | NR | NR | NR | “p=NS” by log-rank test
Kiyotani, 2010 | TAM (282) | 18/63 (29) | 20/135 (15) | 3/84 (3) | NR | NR | NR | NR | IM vs EM 4.44 (1.31–15), [S]^l^ SM vs EM 9.52 (2.79–32.45), [S]^m^ Test-for-trend p-value<0.001

a Time to recurrence (i.e., “relapse-free time” – death events were excluded from analysis) was reported as HR = 2.71 (1.15–6.41) in univariate analysis and 1.85 (0.76–4.52), [S] in multivariate analysis.

b Deaths/person-year.

c “Distant” recurrence-free survival. No definition is reported.

d “Distant” recurrence-free survival. No definition is reported.

e Most analyses performed for groups defined by combination of CYP2D6 genotype and HOXB13/IL17BR gene expression ratio.

f Estimated at 5 years.

g Estimated at 10 years.

h Study reported HR for “time to recurrence”.

i Study also defined a group of patients with “overall reduced CYP2D6 activity”, defined as SM genotype or use of a CYP2D6 inhibitor. Comparing this group with all other patients the HR for recurrence free survival was 1.9 (0.8–4.8), adjusted for LN status.

j This study reported a non-significant p-value=0.413 for “disease free survival” in its main analysis that compared specific genotype groups, set a priori. However, in a post hoc-analysis comparing a poor-metabolizer group (*4/*4, *4/*41, *1/*5, and *2/*5) versus all other genotypes, the reported p-value was 0.016.

k Analyses were stratified by menopausal status, and subcohort assignment (prospective versus retrospective).

l Analyses were stratified by menopausal status, and subcohort assignment (prospective versus retrospective).

m Analyses were stratified by menopausal status, and subcohort assignment (prospective versus retrospective).

#### Studies in the metastatic setting

A single small study from Korea (Table 5, n=16 analyzed samples) reported a statistically significant association between slow (versus extensive) metabolizer status and increased odds for progression and shorter time-to-progression.(27) In addition, the study also demonstrated a higher rate of “clinical benefit”, defined as complete or partial response or stable disease for 24 weeks, among extensive metabolizers (p=0.02).

Table 5 CYP2D6 and tamoxifen for breast cancer: progression (metastatic setting)

Author, year | Progression events, n (%) | | | | Median TTP (months)
| SM | IM | EM | OR, 95% CI | SM | IM | EM | HR, 95% CI
Lim HS, 2007 | 12 (100) | - | 4 (44) | 53 (3–1105)^a^ | 5.0 | - | 21.8 | SM vs IM+EM 3.7 (1.3–10.7) 3.7 (1.2–11.0) [S, ER, PR, T]

a Continuity correction k=0.5 was used to calculate the OR.

Covariate key: A =Age; S= Severity; ER = Estrogen receptor status; PR = Progesterone receptor status; T = treatments.

### Key Question 2 What patient- and disease-related factors affect the test results, their interpretation or their predictive response to therapy?

None of the included studies performed analyses for interaction between the aforementioned factors and CYP2D6-derived metabolizer status to predict response to therapy.

### Key Question 3 How does the gene testing impact the therapeutic choice?

No study explicitly reported details on changes in treatment plans before and after testing.

### Key Question 4 What are the benefits and harms or adverse effects for patients when managed with gene testing?

No study explicitly reported evidence on benefits or harms beyond what is covered in Key Question 1.

## 1.4 Discussion

There were no consistent associations between CYP2D6 polymorphism status and outcomes in tamoxifen treated women with breast cancer across 16 studies included in our systematic review. The included studies were generally small in size, followed poor analytic practices, and differed both in the direction and in the formal statistical significance of their results. It is questionable whether pharmacogenetic testing of germline (heritable) variations in CYP2D6 can predict differential response to adjuvant tamoxifen in women with non-metastatic breast cancer. Further, evidence is severely limited for tamoxifen-treated women with metastatic disease. Our conclusions are analogous to the 2009 ASCO practice guideline update, which states “Given the limited evidence, CYP2D6 testing is currently not recommended in the preventive setting”.(39)

We documented extensive heterogeneity in the definitions of CYP2D6-derived metabolizer categories across the 16 studies (Figure 3). To demonstrate between-study differences in genotype categorizations, we used an arbitrary algorithm that assigned patients with two, one, or none “slow” alleles to slow, intermediate, or extensive metabolizer categories, respectively. We show that studies are inconsistent in their classification of genotypes in metabolizer groups. Further, these inconsistencies are irreconcilable and not dependent of the algorithm we used to standardize metabolizer groups. Figure 3 shows that genotypes in our intermediate metabolizer group were “shifted” towards the extensive or slow metabolizer groups in different studies. Determining the clinically meaningful genetic comparisons in a multi-allelic system is challenging, and offers opportunities for data dredging. Biological rationale can be invoked retroactively and with relative ease(40) in support of even non-intuitive genotype comparisons. For example, the main analysis in the Ramon y Cajal 2009 study was statistically non-significant. In additional analyses the authors grouped 29 different genotypes in a non-intuitive way, and report a p-value of 0.016. Efforts to standardize the definitions of metabolizer groups based on genotype information would allow uniform reporting and facilitate patient-level synthesis of results across studies.

We found no evidence on whether patient or disease relevant factors affect the association between CYP2D6-derived metabolizer status and outcomes in tamoxifen treated women. Such evidence would be obtained by examining interaction effects between the factors of interest and metabolizer status. However, no study performed interaction analyses. Several studies performed simple adjustments for patient level factors. This is not only not informative, but also questionable from a methodological standpoint, as will be discussed below. Arguably, this lack of evidence on patient-level factors may be a moot point, given the equivocal epidemiological evidence on the overall association between testing and outcomes in tamoxifen-treated patients.

Similarly, we found no evidence on whether testing impacts on therapeutic decisions, or on harms associated with testing and its downstream effects. Like all tests, genetic testing exerts most of its effects in an indirect way: test results affect subsequent patient management decisions, which in turn impact on patient-relevant outcomes.(41) Harms are often reported inadequately in RCTs(42) and nonrandomized studies of interventions,(43) and reporting may be even worse for studies of medical tests.

As of this writing there are no validated quality items for evaluating the methodological quality of studies on pharmacogenetic tests. However, methodological observations can be made from basic epidemiological principles.(44) In fact, several contributions to the literature have drawn attention to problems with studies of modification of tamoxifen response.(44–47)

First, most studies are relatively small and thus probably underpowered to detect what would be a plausible effect size for modification of response to tamoxifen and susceptible to type I error (false positive findings). Lash 2009 argues that based on pharmacologic data, and the knowledge that the effect of tamoxifen cannot be bigger than that of aromatase inhibitors, a plausible effect size for the pharmacogenetic effect of CYP2D6 on survival would be at best modest (relative effect no greater than 1.55).(44)

By definition, a pharmacogenetic interaction implies that the genetic factor has differential effects on outcomes in treated versus untreated patients. Almost universally, the studies we identified made the assumption that effects in untreated patients are expected to be zero. Studies based on RCT data provide an opportunity to test for interactions between treatment and CYP2D6-derived metabolizer status, by analyzing both treated and untreated women. No study performed such tests. Instead, all studies implicitly assume that there is no association between CYP2D6-derived metabolizer status and outcomes in women not treated with tamoxifen. Testing for gene by treatment interactions (when possible) is more than a formality; it presents the opportunity to triangulate results on the main effects, i.e., to perform a “reality check” on whether all analyses point to the same direction.

Finally, many studies followed poor analytic practices, by performing statistical adjustments for factors that cannot confound the relationship between CYP2D6 and survival (or other outcomes). Mendelian randomization (the natural randomization of genotypes during mitosis) protects the relationship between germline (heritable) variations in CYP2D6 and outcomes from confounding.[ref] For example, CYP2D6 genotypes are distributed randomly (equally) across women who take SSRIs or other CYP2D6 inhibiting medications and women who do not take such drugs. Because comedication cannot affect anyone’s CYP2D6 genotype, it cannot confound the relationship of CYP2D6 and survival. Table 6 discusses some examples of factors or design characteristics that can confound or bias relationship in classical epidemiology, but not in genetic epidemiology. As discussed elsewhere,(48) genetic associations are not immune to bias; rather, a different set of considerations is applicable to such studies. Multiplicity of comparisons, data dredging, population stratification, and misclassifications of outcomes and genotypes and various biases, such as reporting and publication bias and local-literature bias, are the most common threats to the validity of associations between genetic factors and treatment effect modification.

Table 6 CYP2D6 and tamoxifen for breast cancer: examples of adjustments that are not epidemiologically sound in the effect modification case (See also Lash 2009(47))

Factor/characteristic | Why adjustment for factor is inappropriate
Comedication (or other factors) | - Mendelian randomization: CYP2D6 genotypes are randomly distributed across medication use patterns.; - Even if CYP2D6 predisposed to specific medications, adjustments for medication use are unwarranted: The medication is in the causal path between the genotype and the outcome, and therefore should not be adjusted for (this is called “endogeneity”).
Breast cancer stage | - Mendelian randomization
Adherence to tamoxifen | - Mendelian randomization; - If CYP2D6 affects adherence to tamoxifen, it is an intermediary in the causal path and should not be adjusted for
Sampling bias (convenience sampling of tissues) | - If genotyping is performed after sampling mendelian randomization protects from confounding