# Organization of this technology assessment report

We first describe common methods used throughout this Technology Assessment. We then present the systematic review of each topic in detail, in separate sections. Each of these sections includes a background, additional methods (e.g., topic-specific search strategies, eligibility criteria, or outcomes), results, and discussion:

- Section 1 is variations in CYP2D6 and response to tamoxifen in breast cancer.
- Section 2 is variations in KRAS and response to cetuximab and panitumumab in colorectal cancer.
- Section 3 is variations in BCR-ABL1 and response to imatinib, dasatinib and nilotinib in chronic myeloid leukemia.

The final part of the Technology Assessment discusses crosscutting methodological issues across the three topics.