# Introduction

The next decade may hold great promise for using genetic information to prevent diseases and to manage patients afflicted with these conditions. In the era of evidence-based medicine, the clinical usefulness of alternative prevention and management strategies should be demonstrated, rather than assumed. The subtyping of diseases by cancer genetics and genomics has opened the door to targeted therapies. The ability to target specific therapies to those individuals who can benefit from them will become increasingly urgent among patients with advanced or life-threatening diseases where fewer alternative treatments may be available. The challenges in the integration of cancer pharmacogenetics and targeted therapies in clinical practice require evidence of benefit to the healthcare system, incorporating patient preferences, improving provider education, and anticipating potential ethical and social implications. It is possible that pharmacogenetic testing and the subsequent use of targeted therapies will add cost without producing clinically meaningful improvements in patient outcomes. In the absence of data that can address its clinical utility and value, integration of pharmacogenetic testing in the healthcare system can be a challenge.

## Definition of genetic and pharmacogenetic tests

There are several definitions of genetic tests that are currently available, including the Secretary's Advisory Committee on Genetic Testing^a^. For the purpose of this report we consider tests of human DNA, RNA or proteins for diagnosis, prognosis, risk prediction, treatment guidance or patient monitoring or other clinical purposes, through detection of heritable or nonheritable genetic variations.

a Department of Health and Human Services Secretary's Advisory Committee on Genetic Testing. Request for public comment on a proposed classification methodology for determining level of review for genetic tests. 65(236), 76643–76645. 2000. Federal Register. 2000

A pharmacogenetic test is a specific type of genetic test. It aims to identify patients’ differential response to specific pharmacotherapies. Pharmacogenetic tests are meant to guide treatment strategies, patient evaluations and decisions based on their ability to predict response to treatment in particular clinical contexts.

## Pharmacogenetic tests evaluated in this technology assessment

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report on several pharmacogenetic tests relevant to the Medicare beneficiary population from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the following Evidence-based Practice Center: Tufts EPC (HHSA 290 2007 100551). The aforementioned tests were selected after discussions between AHRQ, CMS and Tufts EPC as examples of tests that are relevant to the Medicare population, evaluate common disease conditions, and meet the definitions of a (pharmaco)genetic test.

These tests are: CYP2D6 testing and response to tamoxifen in patients with breast cancer; KRAS testing and response to cetuximab or panitumumab in patients with colorectal cancer; and BCR-ABL1 mutation testing and response to imatinib, dasatinib and nilotinib in patients with chronic myeloid leukemia. Below is a short description of these tests. More detailed information per test is discussed later in this report.

### CYP2D6 and response to tamoxifen in patients with breast cancer

Tamoxifen is a pro-drug of more biologically potent antagonists of the estrogen receptor in breast tissue such as 4-hydroxytamoxifen and endoxifen, the latter of which is now considered the most active form of tamoxifen metabolites. They are biotransformed through a complicated metabolic pathway, in which CYP2D6 is a key enzyme. Several variant alleles of the CYP2D6 gene have different enzymatic activity and can potentially affect the pathway and metabolite transformation, potentially impacting on patients’ response to tamoxifen treatment.(1) These variants are found in up to 40 percent of the general population.

### KRAS and response to cetuximab or panitumumab in patients with colorectal cancer

Cetuximab targets epidermal growth factor receptor (EGFR), a member of the subclass I of the receptor tyrosine kinase superfamily, which is overexpressed in up to 80 percent of colorectal cancers. Panitumumab is a similarly acting drug. Both drugs block the activation of an EGFR-derived cascade of biochemical events that can ultimately stimulate cellular proliferation, invasion and metastasis. KRAS is an oncogene implicated in the EGFR pathway. Mutations in KRAS can initiate continuous activation of the downstream part of the EGFR-derived cascade regardless of EGFR-dependent activation. Thus, examining the mutation status of KRAS has the potential to predict therapeutic outcomes of treatment strategies involving cetuximab(2;3) or panitumumab.

### BCR-ABL1 and response to imatinib, dasatinib and nilotinib in patients with chronic myeloid leukemia

BCR-ABL1 is a chimeric oncogene (a cancer-causing gene generated by the fusion of parts of genetic material that are normally not adjacent) arising from the translocation between chromosomes 9 and 22. The gene encodes an enzyme (protein) called tyrosine kinase, which is central to the pathogenesis of chronic myelogeneous leukemia. Imatinib, dasatinib and nilotinib are tyrosine kinase inhibitors, i.e., drugs that bind to the tyrosine kinase enzyme and inhibit its activity in a competitive fashion. Specific mutations in BCR-ABL1 have been shown to confer resistance to imatinib both in vitro and in vivo, by affecting the binding of the drug to the tyrosine kinase enzyme. Based of these observations, the detection of mutations of the BCR-ABL1 gene has been proposed as a pharmacogenetic test with potential impact on management decisions.(4)