# Generic methods common to the three topics

This Technology Assessment is based on systematic reviews of the literature. CMS and AHRQ defined the following generic Key Questions that are common to all three topics: The topic-specific Key Questions are obtained from the generic ones by substituting the pharmacogenetic test, the drug intervention, and the cancer of interest. The topic-specific Key Questions are listed in the Methods section of each topic.

## Generic Key Questions

Key Question 1: Does a gene test result predict response to therapy?

Outcomes of interest (“response”) are clinical outcomes such as overall survival, recurrence, and disease progression, and no response to treatment by imaging or laboratory criteria.

Key Question 2: What patient- and disease-related factors affect the test results, their interpretation or their predictive response to therapy?

Examples of patient-level factors are age, sex (when applicable), or racial/ethnic descent. Examples of disease-related factors are tumor type or cancer stage.

Key Question 3: How does the gene testing impact the therapeutic choice?

Only studies that explicitly describe changes in treatment plans before and after testing are considered here. For example, in that case one could record the number (percentage) of times therapy planned before genetic testing changed after the test.

Key Question 4: What are the benefits and harms or adverse effects for patients when managed with gene testing?

Any cognitive, behavioral or other health effects of testing with the three tests of interest. These can include direct effects of the process of testing (e.g., increased anxiety). We would include here downstream effects of testing that are beyond those described in Key Question 1.

## Systematic review process

A systematic review is a structured analysis of the literature that follows a series of predefined steps to answer a collection of well defined key questions: Searching of the literature, screening of citations for inclusion according to predefined criteria, critically reviewing publications in full text to assess their methodological and reporting quality and extract data as per protocol, and synthesizing individual study results qualitatively or quantitatively (meta-analysis).

Details on each systematic review are given in the pertinent sections and Appendices. Here we describe general methods that are common to all three sections.

### Literature searches and screening of citations

For each of the three topics we performed electronic searches in OVID MEDLINE® using specific search strategies from inception through the 4^th^ week of August 2009 with no language restriction. (The actual search strategies are described in the individual Sections.) We limited searches to humans. The first few hundred (300–500) citations in each topic were screened jointly by four authors to ensure that screening criteria were well understood and applied uniformly. Thereafter, three authors screened nonoverlapping sets of the remaining citations.

We complemented the electronic literature searches by perusing the reference lists of included papers and of several relevant narrative or systematic reviews.

### Generic eligibility criteria

For each of the three topics the following generic eligibility criteria were set for all Key Questions. Additional topic specific criteria are described in the Methods section of the specific topics.

Briefly, eligible are studies that report primary data to address the aforementioned questions. These include studies on patients with the diseases of interest and presented information on patient-relevant outcomes (mortality; disease progression; and treatment failure, as defined in each study) stratified by the genetic factor. For Key Question 2, we demanded data from interaction tests.

1. The study associated predefined genetic variations with clinical outcomes in patients treated with the drug of interest
  a. Clinical outcomes of interest were overall or cause specific mortality, recurrence, relapse, or disease progression as defined by each study, and the corresponding time to event outcomes (e.g., time-to-death, time-to-progression).
  b. Treatment failure was defined failure by radiologic criteria for colorectal solid cancers or laboratory criteria (lack of hematologic, cytogenetic or molecular response) for CML.
  c. Somatic genetic variations must be assessed in malignant tissue obtained before administering the drug of interest (for the 2^nd^ and 3^rd^ topic, KRAS and BCR-ABL1). Germline genetic variations may have been ascertained at any time (1^st^ topic, CYP2D6).
2. Eligible designs are
  a. Randomized or nonrandomized studies comparing patient management with versus without pharmacogenetic testing.
  b. Association studies of pharmacogenetic testing and clinical outcomes in patients treated with the drug. These studies resemble a “case-only” design, and assume that the test result does not predict the clinical outcome in untreated patients.
  c. Association studies of pharmacogenetic testing and clinical outcomes examining both patients who received and patients who did not receive the drug of interest. These studies have the opportunity to examine interactions between the test results and treatment type. This analysis can inform on whether the test predicts clinical outcomes in treated rather than untreated patients.^b^
    b A study in both treated and untreated patients that does not perform such interaction analyses between test results and treatment type is effectively as informative as a prediction study in treated-only patients.
3. At least 10 patients analyzed (total).

Especially for Key Question 2 eligible are studies that performed interaction analyses between test results and the factor of interest.^c^ For Key Question 3 we consider only studies that explicitly describe changes in treatment plans before and after testing. For Key Question 4, we refer to evidence on benefits and harms beyond what is covered in Key Question 1 (prediction of response to therapy).

c Studies that simply perform adjustments for the factors of interest do not inform on e.g., how much the strength of the pharmacogenetic association changes across the levels of the factor of interest.

### Data abstraction

We extracted bibliographic information (first author name, journal and year of publication), as well as information on study design including inclusion criteria, patient characteristics (demographic and staging information), treatment characteristics (dosing schedule and compliance), details on genetic testing and frequency of specific genotypes or mutation positions, definitions of outcomes, and numerical data, as described in the individual sections. If a paper did not explicitly report these data, but cited other publications instead, we consulted the cited publications.

### Identification of studies with overlapping populations

We took particular care to identify studies with at least partially overlapping populations. We cross-checked author names, institutions, patient enrollment periods, citations to previous studies, patient numbers, descriptions of treatment protocols, and supplementary materials of all eligible papers to identify sets of potentially overlapping publications. We defined “at least partially overlapping” studies that had any patients in common, because it is often impossible to determine the degree of overlap. In the two systematic reviews (KRAS and BRC-ABL1) where we found such studies, we created undirected graphs to depict which publications were at least partially overlapping. We included all publications in qualitative analyses, but only nonoverlapping publications in meta-analyses. This avoids overcounting, but may introduce undercounting.

### Quality assessment

As of this writing, there are no validated quality items that are specific for assessing pharmacogenetic tests. Therefore, we did not assign quality grades (A, B or C) to studies included in this Technology Assessment. However, we abstracted information on aspects of the design and conduct of the individual studies that we believe is important for interpreting these data. These items include description of patient sampling (representative of parent population or convenience sampling), design of the parent study, (e.g., original data from a well-conducted randomized controlled trial), availability of samples on a large majority of study participants, whether clinically representative patients were assessed, assay methodology (i.e., whether it is predefined and standardized), and analysis techniques (blinding of assessors of test to clinical outcomes and vice versa, and whether appropriate statistical analyses including multivariable adjustments are performed).(5)

### Outcomes

Outcomes of interest were organized into three categories.

- Mortality: Includes all-cause or disease-specific mortality. Apart from analyses of cumulated deaths by a specific time point, pertinent to this category are also time-to-death (overall survival or cause-specific survival) analyses.
- Progression: Includes disease progression, as defined by each study, or a composite of progression or death. Examples are recurrence free survival for resectable breast cancer, which is typically defined as time from study inclusion to local or distant recurrence or death from any causes, and progression free survival for metastatic colorectal cancer, which is typically defined as time from study entry to disease progression assessed by radiologic tests or death from any causes. Apart from analyses of cumulated progression events by a specific time point, pertinent to this category are also time-to-progression (progression-free survival) analyses.
- Tumor responses: These are typically short-term index of treatment efficacy, which may or may not be reliable surrogate outcomes of progression or mortality. For example tumor response is defined based on radiologic imaging criteria in colorectal cancer, whereas several different response assessments such as hematologic (by conventional blood counts and bone marrow examination), cytogenetic (by conventional karyotype analysis or fluorescent in situ hybridization), molecular response (by quantitative real time polymerase chain reaction of BCR-ABL1 transcripts) are performed in chronic myeloid leukemia.

### Synthesis

As will be described in the Results Sections, most eligible studies evaluated associations of genetic test results and outcomes of interest in patients who received the treatment of interest. For mortality and disease progression we evaluate strength of the association between test results and outcomes; for the endpoint of treatment failure we also evaluate test performance by means of sensitivity, specificity and likelihood ratios.

#### Analysis of the strength of the association between test results and outcome of interest

We abstracted data to calculate odds ratios or extracted odds ratio estimates to quantify the strength of the association between test results and outcomes (for analyses of cumulated events) or time-to-clinical-event analyses. We captured both unadjusted (crude) and adjusted effects.

When deemed appropriate, we performed meta-analyses of odds or hazard ratios using the DerSimonian and Laird random effects model. We tested for between-study heterogeneity with Cochran’s Q (considered statistically significant at p<0.10) and assessed its extent with I^2^. I^2^ ranges between 0 and 100 percent and expressed the proportion of between study variability that is attributed to heterogeneity rather than chance.(6;7) We did not set criteria for interpreting I^2^ values.

#### Analysis of the ability of the pharmacogenetic test to predict treatment failure

For each genetic test, we calculated its sensitivity and specificity to predict the occurrence of an event of interest (e.g., progression of disease, relapse or death) using standard methods. Sensitivity is the ability of the test to maximize true positives. Specificity is the ability of the test to minimize false positives.^d^

d Sensitivity is defined as the proportion of people who will experience the outcome that are correctly identified by genetic test. Specificity is the proportion of people who will not experience the outcome that are correctly identified as such by the genetic test. Sensitivity and specificity range between 0 and 100% and higher values imply better diagnostic ability.

A particularly informative graph plots sensitivity against 100% minus their specificity in a plot (commonly known as the ROC space plot). The closer a study point is to the upper left corner of the plot, the better its performance (Figure 1).

The positive and negative likelihood ratios (LR+ and LR−, respectively^e^) quantify the change in the certainty of the “diagnosis” (prediction) conferred by the results of the test. More specifically, the likelihood ratios transform the pretest odds to the posttest odds of a given prediction:

posttest odds = pretest odds × LR

e The likelihood ratios can be conveniently calculated as follows:

L R + = (sensitivity)/(1 − specificity) , L R − = (1 − sensitivity)/(specificity)

If a given pharmacogenetic test has very good ability to predict clinical outcomes of interest, its LR+ will be high (will greatly increase the odds of a positive diagnosis) and its LR− will be low (will diminish substantially the likelihood of the positive diagnosis). A completely non-informative pharmacogenetic test would have likelihood ratios equal to 1 (does not transform the pre-test odds substantially in the equation listed in the text).

For a positive test result, the LR+ would be used in the above relationship; for a negative result, the LR− would be used. Typically, a LR+ of 10 or more and a LR− of 0.1 or less are considered to represent informative tests.(8) Other, more lenient boundaries for LR+ and LR− can be used. The choice of the boundaries is dependent on the decisional context of the test. Studies with high LR+ and low LR− can be readily identified in the square sensitivity/100%-specificity plot, as shown in Figure 1.

Figure 1 Square plot of sensitivity versus 100%-specificity

Four hypothetical studies are depicted in the square sensitivity/100%-specificity plot. The closer a study is to the upper-left corner of the plot, the better its diagnostic ability. Studies lying on the major diagonal of the plot have no diagnostic ability (no better than chance). Studies lying on the left shaded area have LR+ of 10 or more. Studies lying on the top shaded are have LR− of 0.1 or less. Studies lying on the intersection of the grey areas (darker grey polygon) have both LR+>10 and LR−<0.1.(8)

Figure 1. Square plot of sensitivity versus 100%-specificity. (page 8) Figure 1 is a graph that shows so called a receiver operator characteristcs plotting. Four hypothetical studies are depicted in the square space of sensitivity (y axis) versus 100%-specificity (x axis). The closer a study is to the upper-left corner of the space, the better its diagnostic ability. One study with perfect diagnostic ability is plotted on the corner. Studies lying on the major diagonal of the plot have no diagnostic ability (no better than chance), on which thees is one such study with both sensitvity and specificty of 50% plotted. Studies lying on the left shaded area have LR+ of 10 or more, in which one study with high specificity (98%) and not so high sensitivity (60%) is plotted. Studies lying on the top shaded are have LR− of 0.1 or less, in which there is one study with very high sensitivity (98%) and not so very high specificity. Studies lying on the intersection of the grey areas (darker grey polygon) have both LR+>10 and LR−<0.1.

When deemed appropriate, we performed meta-analyses of sensitivity and specificity using a bivariate model with exact binomial likelihood,(9;10) as described in the topic-specific Methods sections.