# Summary

## Background

The challenges in the integration of cancer pharmacogenetics and targeted therapies in clinical practice should require evidence of benefit to the patients (a favorable balance of harms and benefits of testing), cost-effectiveness for the healthcare system, incorporating patient preferences, improving provider education, and anticipating potential ethical and social implications. It is possible that pharmacogenetic testing and the subsequent use of targeted therapies will add cost without producing clinically meaningful improvements in patient outcomes. In the absence of data that can address its clinical utility and value, integration of pharmacogenetic testing in the healthcare system is not straightforward.

This Technology Assessment assesses the evidence on the benefits and harms of three pharmacogenetic tests employed for three different diseases pertinent to the Medicare beneficiary population: variations in CYP2D6 and response to tamoxifen in breast cancer; variations in KRAS and response to cetuximab and panitumumab in colorectal cancer and variations in BCR-ABL1 and response to imatinib, dasatinib and nilotinib in chronic myeloid leukemia. The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the following Evidence-based Practice Center: Tufts EPC (HHSA 290 2007 100551).

## Methods

We performed three systematic reviews of the published literature to address the following Key Questions for each of the aforementioned topics:

1. Does the genetic test result predict response to therapy?
2. What patient- and disease-related factors affect the test results, their interpretation or their predictive response to therapy?
3. How does the gene testing impact the therapeutic choice?
4. What are the benefits and harms or adverse effects for patients when managed with gene testing?

We searched MEDLINE from inception until August 2009. For the CYP2D6 and KRAS systematic reviews the search was updated through the end of March 2010. Details on which studies are considered eligible to address these key questions are described in the Methods Section of the full Technology Assessment. Briefly, eligible are studies that report primary data to address the aforementioned questions. These include studies on patients with the diseases of interest and presented information on patient-relevant outcomes (mortality; disease progression; and treatment failure, as defined in each study) stratified by the genetic factor. Especially for Key Question 2, eligible are studies that performed interaction analyses between test results and the factor of interest. For Key Question 3 we consider only studies that explicitly describe changes in treatment plans before and after testing. For Key Question 4, we refer to evidence on benefits and harms beyond what is covered in Key Question 1 (prediction of response to therapy).

## Results

Our literature searches did not identify any eligible studies for Key Questions 2 (no study reported statistical interactions), 3 (no study explicitly reported treatment plans before and after testing) or 4 (no study explicitly reported evidence on benefits or harms beyond what is covered in Key Question 1).

Thus, we summarize here the relevant evidence identified for Key Question 1 for each topic. Table S1 shows the number of studies that were included in the three systematic reviews.

### Section 1 Variations in CYP2D6 and response to tamoxifen in breast cancer

There were no consistent associations between CYP2D6 polymorphisms and outcomes in tamoxifen treated women with breast cancer across 16 studies included in the systematic review. The included studies were generally small in size, followed poor analytic practices, and differed both in the direction and in the formal statistical significance of their results. It is unclear whether pharmacogenetic testing of germline (heritable) mutations in CYP2D6 can predict differential response to adjuvant tamoxifen in women with non-metastatic breast cancer. Further, evidence is severely limited for tamoxifen-treated women with metastatic disease. Our conclusions are analogous to the 2009 American Society of Clinical Oncology (ASCO) practice guideline update.

We documented extensive heterogeneity in the definitions of CYP2D6-derived metabolizer categories across eligible studies. Determining the clinically meaningful genetic comparisons in a multi-allelic system is challenging, and may be subjected to offers authors opportunities for data dredging. Most studies were relatively small and thus underpowered to detect what would be a plausible effect size for the modification of response to tamoxifen by a single polymorphism.

We found no evidence on whether patient or disease relevant factors affect the association between CYP2D6-derived metabolizer status and outcomes in tamoxifen treated women. Such evidence would be obtained by examining interaction effects between the factors of interest and metabolizer status. However, no study performed such analyses. Several studies performed simple adjustments for patient level factors. This is not only noninformative, but also questionable from an analytic standpoint.

### Section 2 Variations in KRAS and response to cetuximab and panitumumab in colorectal cancer

We identified 47 eligible studies. Of those, 37 were conducted in the second-line metastatic setting, 8 were conducted in the first line metastatic setting and 2 were conducted in the neo-adjuvant setting. When treated with anti-EGFR antibodies, patients with KRAS mutations were less likely to experience treatment benefit, compared to patients whose tumors were wild-type for KRAS mutations, for all outcomes assessed. These results were confirmed in several RCT-based analyses of progression-free survival that demonstrated a significant treatment-by-KRAS mutation interaction in three out of the four cases where such analyses were reported.

The direction of effect was consistent among studies, and formal significance was achieved in the majority of individual studies that reported information on the clinically relevant outcomes of overall and disease-free survival. Most studies pertained to patients who had received previous cytotoxic chemotherapy. These observations are analogous to guidance provided recently by ASCO, the Food and Drug Administration (FDA), and the European Medicines Agency (EMeA).

Although few studies were conducted in the first line setting, for all outcomes and particularly for treatment failure, the predictive ability of KRAS mutations was lower compared to that observed in pre-treated patients. This observation argues for the need for further studies in the first line setting.

Regarding the two different agents, cetuximab and panitumumab, the predictive ability of KRAS mutations appeared to be similar. However, the bulk of available evidence for this comparison was related to studies assessing panitumumab as monotherapy, and in all cases in patients pre-treated with cytotoxic chemotherapy.

### Section 3 Variations in BCR-ABL1 and response to imatinib, dasatinib and nilotinib in chronic myeloid leukemia

We identified 31 eligible studies. The presence of any BCR-ABL1 mutation (that is when considering all mutations together) does not appear to predict differential response to tyrosine kinase inhibitor (TKI) treatments (defined as imatinib-, dasatinib-, and nilotinib-based regimens). There is consistent evidence that presence of the relatively rare T315I mutation can predict TKI treatment failure, mainly in terms of hematologic and cytogenetic response.

The fact that presence of any BCR-ABL1 mutation does not appear to differentiate response to TKI therapies is emblematic of the complexity of this topic: different mutations may confer different resistance to each of the three drugs. Exploring such relationships with systematic reviews of published aggregate data is extremely challenging. Other approaches, including collaborative registries of CML patients are much better suited to address such questions.

Further, the majority of evidence pertains to the short term surrogate outcomes of hematologic, cytogenetic or molecular response. Data on overall or progression-free survival are sparse. Finally, most evidence is on second line TKI treatments, especially dasatinib and nilotinib, and originates from a small number of referral cancer centers where those agents were first-tested before becoming more widely available.

Table S1 Evidence map of studies included in this report

| Breast Cancer CYP2D6 | | Colorectal Cancer KRAS^a^ | | | | | | CML BCR-ABL1*
| Tamoxifen | | Cetuximab | | Panitumumab | | Both | | Imatinib | | | Dasatinib | | Nilotinib
| Adjuvant | Metastatic | 1^st^ line | 2^nd^ line | 1^st^ line | 2^nd^ line | 1^st^ line | 2^nd^ line | | 1^st^ line | 2^nd^ line | 2^nd^ line | 3^rd^ line | 2^nd^ line
Mortality | 7 (1) | 0 | 4 (2) | 20 (1) | 1 (1) | 2 (1) | 0 | 3 (0) | | 1 (0) | 0 | 0 | 0 | 0
Progression | 14 (2) | 1 (0) | 6 (3) | 23 (1) | 1 (1) | 3 (1) | 0 | 5 (0) | | 1 (0) | 1 (0) | 0 | 0 | 0
Treatment Failure | 0 | 1 (0) | 7 (4) | 28 (1) | 1 (1) | 3 (1) | 0 | 6 (0) | HR CyR MolR Comp | 1 (0) 1 (0) 0 1 (0) | 4 (0) 4 (0) 0 0 | 9 (0) 12 (0) 1 (0) 0 | 1 (0) 1 (0) 0 0 | 3 (0) 3 (0) 0 0

a Two additional prospective single arm studies assessed pathologic response in patients receiving cetuximab in combination with chemoradiotherapy for rectal cancer.

Summary table of studies included in this report, organized by topic and outcomes assessed. Numbers in parentheses are RCT-based analyses. HR, Hematologic response. CyR=cytogenetic response. MolR= Molecular response. Comp=composite definition (i.e. hematologic + molecular). Here we only count as “RCTs” randomized trials that compare using vs not using tamoxifen, anti-EGFR antibodies or tyrosine kinase inhibitors, respectively, for the three topics.

### Crosscutting issues

Here we summarize a range of methodological issues that we identified across the three topics. These issues are applicable to all three tests, which have quite different characteristics. In the first topic (CYP2D6 polymorphisms and tamoxifen response modification) we evaluate germline polymorphisms, i.e., heritable common variations. In the other two cases we examine somatic mutations, i.e., genetic variations that are not heritable, and may evolve during the course of the disease. In the KRAS case mutations were relatively frequent, but the T315I mutation in BCR-ABL1 is relatively rare. We comment only on methodological issues that we came across in the three topics; broader consideration of this literature is outside the scope of this work.

#### Study design issues

- Treatment-by-gene (polymorphism or mutation) interactions were often not formally assessed.
- It may not be necessary to design new studies to address pharmacogenetic associations. It is possible to “repurpose” already completed RCTs in which the drugs of interest are tested against a suitable comparator, by genotyping tissue samples from enrollees.
- Studies often had small sample sizes and thus would not be able to reliably identify effects as small as those anticipated for most pharmacogenetic tests (unlike the relatively large effects observed for KRAS) or effects determined by rare genetic variations (such as BCR-ABL1 mutations).

#### Outcomes

- Most studies assessed surrogate short term outcomes of treatment failure, as defined by imaging or laboratory measurements. Data on the clinical outcomes of overall or progression-free survival are sparse.
- In all three examples, we found no evidence on whether testing impacts on therapeutic decisions, or on harms associated with testing and its downstream effects.

#### Heterogeneity in the classification of genetic factors

- We documented extensive heterogeneity in way genetic factors were grouped and analyzed across the included studies.
- These and other challenges limit the usefulness of meta-analysis of aggregate level data, and are better addressed by meta-analyses of individual patient data.

#### Statistical analyses

- Adjustments for potential confounding factors were often not based on sound epidemiological principles.
- Adjustments for multiple comparisons were not documented in the included studies. This is a major issue in genetic epidemiology, because of the large number of possible hypotheses that can be examined.

#### Other issues

- Multiple studies on each topic frequently originated from a limited number of specialized centers, posing problems in identifying nonoverlapping populations, and potentially threaten the generalizability of the findings.