# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Dr. Julian Little
  Professor and Chair, Department of Epidemiology and Community Medicine
  University of Ottawa
  Ontario, Canada
- Dr. Rinaa Punglia
  Assistant Professor
  Harvard Medical School
  Boston, Massachusetts
- Dr. Mark Ratain
  Director, Center for Personalized Therapeutics
  University of Chicago
  Chicago, Illinois
- Dr. David Veenstra
  Associate Professor
  University of Washington
  Seattle, Washington