# References

1 Dezentje VO, Guchelaar HJ, Nortier JW, van d V, Gelderblom H. Clinical implications of CYP2D6 genotyping in tamoxifen treatment for breast cancer. Clin Cancer Res. January. 1. 2009;15(1):15-21. [pmid: 19118028].
2 Jimeno A, Messersmith WA, Hirsch FR, Franklin WA, Eckhardt SG. KRAS mutations and susceptibility to cetuximab and panitumumab in colorectal cancer. Cancer J. March. 2009;15(2):110-113. [pmid: 19390304].
3 Jimeno A, Messersmith WA, Hirsch FR, Franklin WA, Eckhardt SG. KRAS mutations and sensitivity to epidermal growth factor receptor inhibitors in colorectal cancer: practical application of patient selection. J Clin Oncol. March. 1. 2009;27(7):1130-1136. [pmid: 19124802].
4 Druker BJ. Translation of the Philadelphia chromosome into therapy for CML. Blood. December. 15. 2008;112(13):4808-4817. [pmid: 19064740].
5 Mandrekar SJ, Sargent DJ. Clinical trial designs for predictive biomarker validation: theoretical considerations and practical challenges. J Clin Oncol. August. 20. 2009;27(24):4027-4034. [pmid: 19597023].
6 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. June. 15. 2002;21(11):1539-1558. [pmid: 12111919].
7 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. September. 6. 2003;327(7414):557-560. [pmid: 12958120].
8 Jaeschke R, Guyatt GH, Sackett DL. Users' guides to the medical literature. III. How to use an article about a diagnostic test. B. What are the results and will they help me in caring for my patients? The Evidence-Based Medicine Working Group. JAMA. March. 2. 1994;271(9):703-707. [pmid: 8309035].
9 Chu H, Cole SR. Bivariate meta-analysis of sensitivity and specificity with sparse data: a generalized linear mixed model approach. J Clin Epidemiol. December. 2006;59(12):1331-1332. [pmid: 17098577].
10 Reitsma JB, Glas AS, Rutjes AW, Scholten RJ, Bossuyt PM, Zwinderman AH. Bivariate analysis of sensitivity and specificity produces informative summary measures in diagnostic reviews. J Clin Epidemiol. October. 2005;58(10):982-990. [pmid: 16168343].
11 Effects of chemotherapy and hormonal therapy for early breast cancer on recurrence and 15-year survival: an overview of the randomised trials. Lancet. May. 14. 2005;365(9472):1687-1717. [pmid: 15894097].
12 Dowsett M, Cuzick J, Ingle J, Coates A, Forbes J, Bliss J, et al. Meta-analysis of breast cancer outcomes in adjuvant trials of aromatase inhibitors versus tamoxifen. J Clin Oncol. January. 2010;28(3):509-518. [pmid: 19949017].
13 Ring A, Dowsett M. Mechanisms of tamoxifen resistance. Endocr Relat Cancer. December. 2004;11(4):643-658. [pmid: 15613444].
14 Musgrove EA, Sutherland RL. Biological determinants of endocrine resistance in breast cancer. Nat Rev Cancer. September. 2009;9(9):631-643. [pmid: 19701242].
15 Goetz MP, Suman VJ, Couch FJ, Ames MM, Rae JM, Erlander MG, et al. Cytochrome P450 2D6 and homeobox 13/interleukin-17B receptor: combining inherited and tumor gene markers for prediction of tamoxifen resistance. Clinical Cancer Research. September. 15. 2008;14(18):5864-5868. [pmid: 18794098].
16 Hoskins JM, Carey LA, McLeod HL. CYP2D6 and tamoxifen: DNA matters in breast cancer. Nat Rev Cancer. August. 2009;9(8):576-586. [pmid: 19629072].
17 Desta Z, Ward BA, Soukhova NV, Flockhart DA. Comprehensive evaluation of tamoxifen sequential biotransformation by the human cytochrome P450 system in vitro: prominent roles for CYP3A and CYP2D6. J Pharmacol Exp Ther. September. 2004;310(3):1062-1075. [pmid: 15159443].
18 Ingelman-Sundberg M. Genetic polymorphisms of cytochrome P450 2D6 (CYP2D6): clinical consequences, evolutionary aspects and functional diversity. Pharmacogenomics J. 2005;5(1):6-13. [pmid: 15492763].
19 Johnson MD, Zuo H, Lee KH, Trebley JP, Rae JM, Weatherman RV, et al. Pharmacological characterization of 4-hydroxy-N-desmethyl tamoxifen, a novel active metabolite of tamoxifen. Breast Cancer Res Treat. May. 2004;85(2):151-159. [pmid: 15111773].
20 Nelson DR, Zeldin DC, Hoffman SM, Maltais LJ, Wain HM, Nebert DW. Comparison of cytochrome P450 (CYP) genes from the mouse and human genomes, including nomenclature recommendations for genes, pseudogenes and alternative-splice variants. Pharmacogenetics. January. 2004;14(1):1-18. [pmid: 15128046].
21 Yu KD, Shao ZM. Genetic matters of CYP2D6 in breast cancer: copy number variations and nucleotide polymorphisms. Nat Rev Cancer. November. 2009;9(11):842. [pmid: 19866496].
22 Gaedigk A, Ndjountche L, Divakaran K, Dianne BL, Zineh I, Oberlander TF, et al. Cytochrome P4502D6 (CYP2D6) gene locus heterogeneity: characterization of gene duplication events. Clin Pharmacol Ther. February. 2007;81(2):242-251. [pmid: 17259947].
23 Jin Y, Desta Z, Stearns V, Ward B, Ho H, Lee KH, et al. CYP2D6 genotype, antidepressant use, and tamoxifen metabolism during adjuvant breast cancer treatment. J Natl Cancer Inst. January. 5. 2005;97(1):30-39. [pmid: 15632378].
24 Bijl MJ, van Schaik RH, Lammers LA, Hofman A, Vulto AG, van GT, et al. The CYP2D6*4 polymorphism affects breast cancer survival in tamoxifen users. Breast Cancer Res Treat. November. 2009;118(1):125-130. [pmid: 19189212].
25 Goetz MP, Rae JM, Suman VJ, Safgren SL, Ames MM, Visscher DW, et al. Pharmacogenetics of tamoxifen biotransformation is associated with clinical outcomes of efficacy and hot flashes.[see comment]. Journal of Clinical Oncology. December. 20. 2005;23(36):9312-9318. [pmid: 16361630].
26 Kiyotani K, Mushiroda T, Sasa M, Bando Y, Sumitomo I, Hosono N, et al. Impact of CYP2D6*10 on recurrence-free survival in breast cancer patients receiving adjuvant tamoxifen therapy.[see comment]. Cancer Science. May. 2008;99(5):995-999. [pmid: 18294285].
27 Lim HS, Ju LH, Seok LK, Sook LE, Jang IJ, Ro J. Clinical implications of CYP2D6 genotypes predictive of tamoxifen pharmacokinetics in metastatic breast cancer.[see comment]. Journal of Clinical Oncology. September. 1. 2007;25(25):3837-3845. [pmid: 17761971].
28 Newman WG, Hadfield KD, Latif A, Roberts SA, Shenton A, McHague C, et al. Impaired tamoxifen metabolism reduces survival in familial breast cancer patients. Clinical Cancer Research. September. 15. 2008;14(18):5913-5918. [pmid: 18794105].
29 Nowell SA, Ahn J, Rae JM, Scheys JO, Trovato A, Sweeney C, et al. Association of genetic variation in tamoxifen-metabolizing enzymes with overall survival and recurrence of disease in breast cancer patients. Breast Cancer Research & Treatment. June. 2005;91(3):249-258. [pmid: 15952058].
30 Okishiro M, Taguchi T, Jin KS, Shimazu K, Tamaki Y, Noguchi S. Genetic polymorphisms of CYP2D6 10 and CYP2C19 2, 3 are not associated with prognosis, endometrial thickness, or bone mineral density in Japanese breast cancer patients treated with adjuvant tamoxifen. Cancer. March. 1. 2009;115(5):952-961. [pmid: 19156902].
31 Ramon YC, Altes A, Pare L, Del RE, Alonso C, Barnadas A, et al. Impact of CYP2D6 polymorphisms in tamoxifen adjuvant breast cancer treatment. Breast Cancer Res Treat. 2009. February. 3.
32 Schroth W, Antoniadou L, Fritz P, Schwab M, Muerdter T, Zanger UM, et al. Breast cancer treatment outcome with adjuvant tamoxifen relative to patient CYP2D6 and CYP2C19 genotypes.[see comment]. Journal of Clinical Oncology. November. 20. 2007;25(33):5187-5193. [pmid: 18024866].
33 Wegman P, Vainikka L, Stal O, Nordenskjold B, Skoog L, Rutqvist LE, et al. Genotype of metabolic enzymes and the benefit of tamoxifen in postmenopausal breast cancer patients.[see comment]. Breast Cancer Research. 2005;7(3):R284-R290. [pmid: 15987423].
34 Wegman P, Elingarami S, Carstensen J, Stal O, Nordenskjold B, Wingren S. Genetic variants of cyp3a5, cyp2d6, sult1a1, ugt2b15 and tamoxifen response in postmenopausal patients with breast cancer. Breast Cancer Research. 2007;9(1):R7. [pmid: 17244352].
35 Xu Y, Sun Y, Yao L, Shi L, Wu Y, Ouyang T, et al. Association between CYP2D6 *10 genotype and survival of breast cancer patients receiving tamoxifen treatment. Annals of Oncology. August. 2008;19(8):1423-1429. [pmid: 18407954].
36 Toyama T, Yamashita H, Sugiura H, Kondo N, Iwase H, Fujii Y. No association between CYP2D6*10 genotype and survival of node-negative Japanese breast cancer patients receiving adjuvant tamoxifen treatment. Jpn J Clin Oncol. October. 2009;39(10):651-656. [pmid: 19596663].
37 Kiyotani K, Mushiroda T, Imamura CK, Hosono N, Tsunoda T, Kubo M, et al. Significant effect of polymorphisms in CYP2D6 and ABCC2 on clinical outcomes of adjuvant tamoxifen therapy for breast cancer patients. J Clin Oncol. March. 10. 2010;28(8):1287-1293. [pmid: 20124171].
38 Schroth W, Goetz MP, Hamann U, Fasching PA, Schmidt M, Winter S, et al. Association between CYP2D6 polymorphisms and outcomes among women with early stage breast cancer treated with tamoxifen. JAMA. October. 7. 2009;302(13):1429-1436. [pmid: 19809024].
39 Visvanathan K, Chlebowski RT, Hurley P, Col NF, Ropka M, Collyar D, et al. American society of clinical oncology clinical practice guideline update on the use of pharmacologic interventions including tamoxifen, raloxifene, and aromatase inhibition for breast cancer risk reduction. J Clin Oncol. July. 1. 2009;27(19):3235-3258. [pmid: 19470930].
40 Ioannidis JP, Polyzos NP, Trikalinos TA. Selective discussion and transparency in microarray research findings for cancer outcomes. Eur J Cancer. September. 2007;43(13):1999-2010. [pmid: 17629475].
41 Bossuyt PM, McCaffery K. Additional patient outcomes and pathways in evaluations of testing. Med Decis Making. September. 2009;29(5):E30-E38. [pmid: 19726782].
42 Ioannidis JP, Lau J. Completeness of safety reporting in randomized trials: an evaluation of 7 medical areas. JAMA. January. 24. 2001;285(4):437-443. [pmid: 11242428].
43 Papanikolaou PN, Christidi GD, Ioannidis JP. Comparison of evidence on harms of medical interventions in randomized and nonrandomized studies. CMAJ. February. 28. 2006;174(5):635-641. [pmid: 16505459].
44 Lash TL, Ahern TP, Cronin-Fenton D, Garne JP, Hamilton-Dutoit S, Kvistgaard ME, et al. Modification of tamoxifen response: what have we learned?. J Clin Oncol. April. 1. 2008;26(10):1764-1765. [pmid: 18375910].
45 Ahern TP, Pedersen L, Cronin-Fenton DP, Sorensen HT, Lash TL. No increase in breast cancer recurrence with concurrent use of tamoxifen and some CYP2D6-inhibiting medications. Cancer Epidemiol Biomarkers Prev. September. 2009;18(9):2562-2564. [pmid: 19690182].
46 Lash TL, Ahern TP, Cronin-Fenton D, Garne JP, Hamilton-Dutoit S, Sorensen HT. Comment on 'Impact of CYP2D6*10 on recurrence-free survival in breast cancer patients receiving adjuvant tamoxifen therapy'. Cancer Sci. August. 2008;99(8):1706-1707. [pmid: 18754887].
47 Lash TL, Lien EA, Sorensen HT, Hamilton-Dutoit S. Genotype-guided tamoxifen therapy: time to pause for reflection?. Lancet Oncol. August. 2009;10(8):825-833. [pmid: 19647203].
48 Colhoun HM, McKeigue PM, Davey SG. Problems of reporting genetic associations with complex outcomes. Lancet. March. 8. 2003;361(9360):865-872. [pmid: 12642066].
49 Hynes NE, Lane HA. ERBB receptors and cancer: the complexity of targeted inhibitors. Nat Rev Cancer. May. 2005;5(5):341-354. [pmid: 15864276].
50 Baselga J. Why the epidermal growth factor receptor?. The rationale for cancer therapy. Oncologist. Suppl 4. 2002;7:2-8. [pmid: 12202782].
51 Chabner BA, Roberts TG Jr. Timeline: Chemotherapy and the war on cancer. Nat Rev Cancer. January. 2005;5(1):65-72. [pmid: 15630416].
52 Goldstein NI, Prewett M, Zuklys K, Rockwell P, Mendelsohn J. Biological efficacy of a chimeric antibody to the epidermal growth factor receptor in a human tumor xenograft model. Clin Cancer Res. November. 1995;1(11):1311-1318. [pmid: 9815926].
53 Schreiber AB, Lax I, Yarden Y, Eshhar Z, Schlessinger J. Monoclonal antibodies against receptor for epidermal growth factor induce early and delayed effects of epidermal growth factor. Proc Natl Acad Sci U S A. December. 1981;78(12):7535-7539. [pmid: 6278478].
54 Siena S, Sartore-Bianchi A, Di NF, Balfour J, Bardelli A. Biomarkers predicting clinical outcome of epidermal growth factor receptor-targeted therapy in metastatic colorectal cancer. J Natl Cancer Inst. October. 7. 2009;101(19):1308-1324. [pmid: 19738166].
55 Saltz LB, Meropol NJ, Loehrer PJ Sr, Needle MN, Kopit J, Mayer RJ. Phase II trial of cetuximab in patients with refractory colorectal cancer that expresses the epidermal growth factor receptor. J Clin Oncol. April. 1. 2004;22(7):1201-1208. [pmid: 14993230].
56 Chung KY, Shia J, Kemeny NE, Shah M, Schwartz GK, Tse A, et al. Cetuximab shows activity in colorectal cancer patients with tumors that do not express the epidermal growth factor receptor by immunohistochemistry. J Clin Oncol. March. 20. 2005;23(9):1803-1810. [pmid: 15677699].
57 Saltz L. Epidermal growth factor receptor-negative colorectal cancer: is there truly such an entity?. Clin Colorectal Cancer. November. Suppl 2. 2005;5:S98-S100. [pmid: 16336755].
58 Bokemeyer C, Bondarenko I, Makhson A, Hartmann JT, Aparicio J, de BF, et al. Fluorouracil, leucovorin, and oxaliplatin with and without cetuximab in the first-line treatment of metastatic colorectal cancer.[see comment]. Journal of Clinical Oncology. February. 10. 2009;27(5):663-671. [pmid: 19114683].
59 Amado RG, Wolf M, Peeters M, Van CE, Siena S, Freeman DJ, et al. Wild-type KRAS is required for panitumumab efficacy in patients with metastatic colorectal cancer.[see comment]. Journal of Clinical Oncology. April. 1. 2008;26(10):1626-1634. [pmid: 18316791].
60 Jonker DJ, O'Callaghan CJ, Karapetis CS, Zalcberg JR, Tu D, Au HJ, et al. Cetuximab for the treatment of colorectal cancer. N Engl J Med. November. 15. 2007;357(20):2040-2048. [pmid: 18003960].
61 Van CE, Kohne CH, Hitre E, Zaluski J, Chang Chien CR, Makhson A, et al. Cetuximab and chemotherapy as initial treatment for metastatic colorectal cancer. New England Journal of Medicine. April. 2. 2009;360(14):1408-1417. [pmid: 19339720].
62 Malumbres M, Barbacid M. RAS oncogenes: the first 30 years. Nat Rev Cancer. June. 2003;3(6):459-465. [pmid: 12778136].
63 Walther A, Johnstone E, Swanton C, Midgley R, Tomlinson I, Kerr D. Genetic prognostic and predictive markers in colorectal cancer. Nat Rev Cancer. July. 2009;9(7):489-499. [pmid: 19536109].
64 Porta M, Crous-Bou M, Wark PA, Vineis P, Real FX, Malats N, et al. Cigarette smoking and K-ras mutations in pancreas, lung and colorectal adenocarcinomas: Etiopathogenic similarities, differences and paradoxes. Mutat Res. September. 2009;682(2–3):83-93. [pmid: 19651236].
65 Bengala C, Bettelli S, Bertolini F, Salvi S, Chiara S, Sonaglio C, et al. Epidermal growth factor receptor gene copy number, K-ras mutation and pathological response to preoperative cetuximab, 5-FU and radiation therapy in locally advanced rectal cancer. Annals of Oncology. March. 2009;20(3):469-474. [pmid: 19095777].
66 Benvenuti S, Sartore-Bianchi A, Di NF, Zanon C, Moroni M, Veronese S, et al. Oncogenic activation of the RAS/RAF signaling pathway impairs the response of metastatic colorectal cancers to anti-epidermal growth factor receptor antibody therapies. Cancer Research. March. 15. 2007;67(6):2643-2648. [pmid: 17363584].
67 Bibeau F, Lopez-Crapez E, Di FF, Thezenas S, Ychou M, Blanchard F, et al. Impact of Fc{gamma}RIIa-Fc{gamma}RIIIa polymorphisms and KRAS mutations on the clinical outcome of patients with metastatic colorectal cancer treated with cetuximab plus irinotecan. Journal of Clinical Oncology. March. 1. 2009;27(7):1122-1129. [pmid: 19164213].
68 Cappuzzo F, Varella-Garcia M, Finocchiaro G, Skokan M, Gajapathy S, Carnaghi C, et al. Primary resistance to cetuximab therapy in EGFR FISH-positive colorectal cancer patients. British Journal of Cancer. July. 8. 2008;99(1):83-89. [pmid: 18577988].
69 De RW, Piessevaux H, De SJ, Janssens M, De HG, Personeni N, et al. KRAS wild-type state predicts survival and is associated to early radiological response in metastatic colorectal cancer treated with cetuximab. Annals of Oncology. March. 2008;19(3):508-515. [pmid: 17998284].
70 Debucquoy A, Haustermans K, Daemen A, Aydin S, Libbrecht L, Gevaert O, et al. Molecular response to cetuximab and efficacy of preoperative cetuximab-based chemoradiation in rectal cancer.[see comment]. Journal of Clinical Oncology. June. 10. 2009;27(17):2751-2757. [pmid: 19332731].
71 Di NF, Martini M, Molinari F, Sartore-Bianchi A, Arena S, Saletti P, et al. Wild-type BRAF is required for response to panitumumab or cetuximab in metastatic colorectal cancer.[see comment]. Journal of Clinical Oncology. December. 10. 2008;26(35):5705-5712. [pmid: 19001320].
72 Di FF, Blanchard F, Charbonnier F, Le PF, Lamy A, Galais MP, et al. Clinical relevance of KRAS mutation detection in metastatic colorectal cancer treated by Cetuximab plus chemotherapy.[see comment]. British Journal of Cancer. April. 23. 2007;96(8):1166-1169. [pmid: 17375050].
73 Frattini M, Saletti P, Romagnani E, Martin V, Molinari F, Ghisletta M, et al. PTEN loss of expression predicts cetuximab efficacy in metastatic colorectal cancer patients. British Journal of Cancer. October. 22. 2007;97(8):1139-1145. [pmid: 17940504].
74 Freeman DJ, Juan T, Reiner M, Hecht JR, Meropol NJ, Berlin J, et al. Association of K-ras mutational status and clinical outcomes in patients with metastatic colorectal cancer receiving panitumumab alone. Clinical Colorectal Cancer. May. 2008;7(3):184-190. [pmid: 18621636].
75 Garm Spindler KL, Pallisgaard N, Rasmussen AA, Lindebjerg J, Andersen RF, Cruger D, et al. The importance of KRAS mutations and EGF61A>G polymorphism to the effect of cetuximab and irinotecan in metastatic colorectal cancer. Annals of Oncology. May. 2009;20(5):879-884. [pmid: 19179548].
76 Goncalves A, Esteyries S, Taylor-Smedra B, Lagarde A, Ayadi M, Monges G, et al. A polymorphism of EGFR extracellular domain is associated with progression free-survival in metastatic colorectal cancer patients receiving cetuximab-based treatment. BMC Cancer. 2008;8:169. [pmid: 18544172].
77 Karapetis CS, Khambata-Ford S, Jonker DJ, O'Callaghan CJ, Tu D, Tebbutt NC, et al. K-ras mutations and benefit from cetuximab in advanced colorectal cancer.[see comment]. New England Journal of Medicine. October. 23. 2008;359(17):1757-1765. [pmid: 18946061].
78 Khambata-Ford S, Garrett CR, Meropol NJ, Basik M, Harbison CT, Wu S, et al. Expression of epiregulin and amphiregulin and K-ras mutation status predict disease control in metastatic colorectal cancer patients treated with cetuximab.[see comment]. Journal of Clinical Oncology. August. 1. 2007;25(22):3230-3237. [pmid: 17664471].
79 Lievre A, Bachet JB, Boige V, Cayre A, Le CD, Buc E, et al. KRAS mutations as an independent prognostic factor in patients with advanced colorectal cancer treated with cetuximab.[see comment]. Journal of Clinical Oncology. January. 20. 2008;26(3):374-379. [pmid: 18202412].
80 Lievre A, Bachet JB, Le CD, Boige V, Landi B, Emile JF, et al. KRAS mutation status is predictive of response to cetuximab therapy in colorectal cancer. Cancer Research. April. 15. 2006;66(8):3992-3995. [pmid: 16618717].
81 Loupakis F, Ruzzo A, Cremolini C, Vincenzi B, Salvatore L, Santini D, et al. KRAS codon 61, 146 and BRAF mutations predict resistance to cetuximab plus irinotecan in KRAS codon 12 and 13 wild-type metastatic colorectal cancer. British Journal of Cancer. August. 18. 2009;101(4):715-721. [pmid: 19603018].
82 Loupakis F, Pollina L, Stasi I, Ruzzo A, Scartozzi M, Santini D, et al. PTEN expression and KRAS mutations on primary tumors and metastases in the prediction of benefit from cetuximab plus irinotecan for patients with metastatic colorectal cancer. Journal of Clinical Oncology. June. 1. 2009;27(16):2622-2629. [pmid: 19398573].
83 Lurje G, Nagashima F, Zhang W, Yang D, Chang HM, Gordon MA, et al. Polymorphisms in cyclooxygenase-2 and epidermal growth factor receptor are associated with progression-free survival independent of K-ras in metastatic colorectal cancer patients treated with single-agent cetuximab. Clinical Cancer Research. December. 1. 2008;14(23):7884-7895. [pmid: 19047118].
84 Molinari F, Martin V, Saletti P, De DS, Spitale A, Camponovo A, et al. Differing deregulation of EGFR and downstream proteins in primary colorectal cancer and related metastatic sites may be clinically relevant. British Journal of Cancer. April. 7. 2009;100(7):1087-1094. [pmid: 19293803].
85 Moroni M, Veronese S, Benvenuti S, Marrapese G, Sartore-Bianchi A, Di NF, et al. Gene copy number for epidermal growth factor receptor (EGFR) and clinical response to antiEGFR treatment in colorectal cancer: a cohort study.[see comment]. Lancet Oncology. May. 2005;6(5):279-286.
86 Muro K, Yoshino T, Doi T, Shirao K, Takiuchi H, Hamamoto Y, et al. A phase 2 clinical trial of panitumumab monotherapy in Japanese patients with metastatic colorectal cancer. Japanese Journal of Clinical Oncology. May. 2009;39(5):321-326. [pmid: 19287023].
87 Oden-Gangloff A, Di FF, Bibeau F, Lamy A, Bougeard G, Charbonnier F, et al. TP53 mutations predict disease control in metastatic colorectal cancer treated with cetuximab-based chemotherapy. British Journal of Cancer. April. 21. 2009;100(8):1330-1335. [pmid: 19367287].
88 Perrone F, Lampis A, Orsenigo M, Di BM, Gevorgyan A, Losa M, et al. PI3KCA/PTEN deregulation contributes to impaired responses to cetuximab in metastatic colorectal cancer patients. Annals of Oncology. January. 2009;20(1):84-90. [pmid: 18669866].
89 Prenen H, De SJ, Jacobs B, De RW, Biesmans B, Claes B, et al. PIK3CA mutations are not a major determinant of resistance to the epidermal growth factor receptor inhibitor cetuximab in metastatic colorectal cancer. Clinical Cancer Research. May. 1. 2009;15(9):3184-3188. [pmid: 19366826].
90 Sartore-Bianchi A, Martini M, Molinari F, Veronese S, Nichelatti M, Artale S, et al. PIK3CA mutations in colorectal cancer are associated with clinical resistance to EGFR-targeted monoclonal antibodies. Cancer Research. March. 1. 2009;69(5):1851-1857. [pmid: 19223544].
91 Tol J, Koopman M, Cats A, Rodenburg CJ, Creemers GJ, Schrama JG, et al. Chemotherapy, bevacizumab, and cetuximab in metastatic colorectal cancer.[see comment]. New England Journal of Medicine. February. 5. 2009;360(6):563-572. [pmid: 19196673].
92 Yen LC, Yeh YS, Chen CW, Wang HM, Tsai HL, Lu CY, et al. Detection of KRAS oncogene in peripheral blood as a predictor of the response to cetuximab plus chemotherapy in patients with metastatic colorectal cancer. Clinical Cancer Research. July. 1. 2009;15(13):4508-4513. [pmid: 19549774].
93 Hecht JR, Mitchell E, Chidiac T, Scroggin C, Hagenstad C, Spigel D, et al. A randomized phase IIIB trial of chemotherapy, bevacizumab, and panitumumab compared with chemotherapy and bevacizumab alone for metastatic colorectal cancer. J Clin Oncol. February. 10. 2009;27(5):672-680. [pmid: 19114685].
94 Tabernero J, Cervantes A, Rivera F, Martinelli E, Rojo F, von HA, et al. Pharmacogenomic and pharmacoproteomic studies of cetuximab in metastatic colorectal cancer: biomarker analysis of a phase I dose-escalation study. J Clin Oncol. March. 1. 2010;28(7):1181-1189. [pmid: 20100964].
95 Folprecht G, Gruenberger T, Bechstein WO, Raab HR, Lordick F, Hartmann JT, et al. Tumour response and secondary resectability of colorectal liver metastases following neoadjuvant chemotherapy with cetuximab: the CELIM randomised phase 2 trial. Lancet Oncol. January. 2010;11(1):38-47. [pmid: 19942479].
96 Yen LC, Uen YH, Wu DC, Lu CY, Yu FJ, Wu IC, et al. Activating KRAS mutations and overexpression of epidermal growth factor receptor as independent predictors in metastatic colorectal cancer patients treated with cetuximab. Ann Surg. February. 2010;251(2):254-260. [pmid: 20010090].
97 Jacobs B, De RW, Piessevaux H, Van OR, Biesmans B, De SJ, et al. Amphiregulin and epiregulin mRNA expression in primary tumors predicts outcome in metastatic colorectal cancer treated with cetuximab. J Clin Oncol. October. 2009;27(30):5068-5074. [pmid: 19738126].
98 Laurent-Puig P, Cayre A, Manceau G, Buc E, Bachet JB, Lecomte T, et al. Analysis of PTEN, BRAF, and EGFR status in determining benefit from cetuximab therapy in wild-type KRAS metastatic colon cancer. J Clin Oncol. December. 10. 2009;27(35):5924-5930. [pmid: 19884556].
99 Paule B, Castagne V, Picard V, Saffroy R, Adam R, Guettier C, et al. MDR1 polymorphism role in patients treated with cetuximab and irinotecan in irinotecan refractory colorectal cancer. Med Oncol. 2009. October. 28.
100 Sartore-Bianchi A, Di NF, Nichelatti M, Molinari F, De DS, Saletti P, et al. Multi-determinants analysis of molecular alterations for predicting clinical benefit to EGFR-targeted monoclonal antibodies in colorectal cancer. PLoS One. October. 2. 2009;4(10):e7287. [pmid: 19806185].
101 Sohn BS, Kim TW, Lee JL, Ryu MH, Chang HM, Kang YK, et al. The role of KRAS mutations in predicting the efficacy of cetuximab-plus-irinotecan therapy in irinotecan-refractory Korean metastatic colorectal cancer patients. Oncology. 2009;77(3–4):224-230. [pmid: 19738388].
102 Souglakos J, Philips J, Wang R, Marwah S, Silver M, Tzardi M, et al. Prognostic and predictive value of common mutations for treatment response and survival in patients with metastatic colorectal cancer. Br J Cancer. August. 4. 2009;101(3):465-472. [pmid: 19603024].
103 Chung CH, Seeley EH, Roder H, Grigorieva J, Tsypin M, Roder J, et al. Detection of tumor epidermal growth factor receptor pathway dependence by serum mass spectrometry in cancer patients. Cancer Epidemiol Biomarkers Prev. February. 2010;19(2):358-365. [pmid: 20086114].
104 Graziano F, Canestrari E, Loupakis F, Ruzzo A, Galluccio N, Santini D, et al. Genetic modulation of the Let-7 microRNA binding to KRAS 3'-untranslated region and survival of metastatic colorectal cancer patients treated with salvage cetuximab-irinotecan. Pharmacogenomics J. 2010. February. 23.
105 Perkins G, Lievre A, Ramacci C, Meatchi T, de RA, Emile JF, et al. Additional value of EGFR downstream signaling phosphoprotein expression to KRAS status for response to anti-EGFR antibodies in colorectal cancer. Int J Cancer. 2010. January. 4.
106 Montagut C, Iglesias M, Arumi M, Bellosillo B, Gallen M, Martinez-Fernandez A, et al. Mitogen-activated protein kinase phosphatase-1 (MKP-1) impairs the response to anti-epidermal growth factor receptor (EGFR) antibody cetuximab in metastatic colorectal cancer patients. Br J Cancer. March. 30. 2010;102(7):1137-1144. [pmid: 20234366].
107 Scartozzi M, Mandolesi A, Giampieri R, Pierantoni C, Loupakis F, Zaniboni A, et al. Insulin-like growth factor 1 expression correlates with clinical outcome in K-RAS wild type colorectal cancer patients treated with cetuximab and irinotecan. Int J Cancer. 2010. January. 22.
108 Personeni N, Fieuws S, Piessevaux H, De HG, De SJ, Biesmans B, et al. Clinical usefulness of EGFR gene copy number as a predictive marker in colorectal cancer patients treated with cetuximab: a fluorescent in situ hybridization study. Clin Cancer Res. September. 15. 2008;14(18):5869-5876. [pmid: 18794099].
109 Dworak O, Keilholz L, Hoffmann A. Pathological features of rectal cancer after preoperative radiochemotherapy. Int J Colorectal Dis. 1997;12(1):19-23. [pmid: 9112145].
110 Wheeler JM, Warren BF, Mortensen NJ, Ekanyaka N, Kulacoglu H, Jones AC, et al. Quantification of histologic regression of rectal cancer after irradiation: a proposal for a modified staging system. Dis Colon Rectum. August. 2002;45(8):1051-1056. [pmid: 12195189].
111 Allegra CJ, Jessup JM, Somerfield MR, Hamilton SR, Hammond EH, Hayes DF, et al. American Society of Clinical Oncology provisional clinical opinion: testing for KRAS gene mutations in patients with metastatic colorectal carcinoma to predict response to anti-epidermal growth factor receptor monoclonal antibody therapy. J Clin Oncol. April. 20. 2009;27(12):2091-2096. [pmid: 19188670].
112 Linardou H, Dahabreh IJ, Kanaloupiti D, Siannis F, Bafaloukos D, Kosmidis P, et al. Assessment of somatic k-RAS mutations as a mechanism associated with resistance to EGFR-targeted agents: a systematic review and meta-analysis of studies in advanced non-small-cell lung cancer and metastatic colorectal cancer. Lancet Oncol. October. 2008;9(10):962-972. [pmid: 18804418].
113 Hebbar M, Fournier P, Romano O. KRAS mutational status assessment in patients with metastatic colorectal cancer: are the clinical implications so clear?. Eur J Cancer Care (Engl ). 2009. August. 20.
114 Mittmann N, Au HJ, Tu D, O'Callaghan CJ, Isogai PK, Karapetis CS, et al. Prospective cost-effectiveness analysis of cetuximab in metastatic colorectal cancer: evaluation of National Cancer Institute of Canada Clinical Trials Group CO. 17 trial. J Natl Cancer Inst. September. 2. 2009;101(17):1182-1192. [pmid: 19666851].
115 Jemal A, Siegel R, Ward E, Hao Y, Xu J, Thun MJ. Cancer statistics, 2009. CA Cancer J Clin. July. 2009;59(4):225-249. [pmid: 19474385].
116 Deininger MW. Milestones and monitoring in patients with CML treated with imatinib. Hematology Am Soc Hematol Educ Program. 2008:419-426. [pmid: 19074120].
117 Ross DM, Hughes TP. Current and emerging tests for the laboratory monitoring of chronic myeloid leukaemia and related disorders. Pathology. April. 2008;40(3):231-246. [pmid: 18428043].
118 Baccarani M, Cortes J, Pane F, Niederwieser D, Saglio G, Apperley J, et al. Chronic Myeloid Leukemia: An Update of Concepts and Management Recommendations of European LeukemiaNet. J Clin Oncol. 2009. November. 2.
119 Hochhaus A, O'Brien SG, Guilhot F, Druker BJ, Branford S, Foroni L, et al. Six-year follow-up of patients receiving imatinib for the first-line treatment of chronic myeloid leukemia. Leukemia. June. 2009;23(6):1054-1061. [pmid: 19282833].
120 Quintas-Cardama A, Kantarjian HM, Cortes JE. Mechanisms of primary and secondary resistance to imatinib in chronic myeloid leukemia. Cancer Control. April. 2009;16(2):122-131. [pmid: 19337198].
121 Gorre ME, Mohammed M, Ellwood K, Hsu N, Paquette R, Rao PN, et al. Clinical resistance to STI-571 cancer therapy caused by BCR-ABL gene mutation or amplification. Science. August. 3. 2001;293(5531):876-880. [pmid: 11423618].
122 Jones D, Kamel-Reid S, Bahler D, Dong H, Elenitoba-Johnson K, Press R, et al. Laboratory practice guidelines for detecting and reporting BCR-ABL drug resistance mutations in chronic myelogenous leukemia and acute lymphoblastic leukemia: a report of the Association for Molecular Pathology. J Mol Diagn. January. 2009;11(1):4-11. [pmid: 19095773].
123 Hughes T, Deininger M, Hochhaus A, Branford S, Radich J, Kaeda J, et al. Monitoring CML patients responding to treatment with tyrosine kinase inhibitors: review and recommendations for harmonizing current methodology for detecting BCR-ABL transcripts and kinase domain mutations and for expressing results. Blood. July. 1. 2006;108(1):28-37. [pmid: 16522812].
124 Baccarani M, Saglio G, Goldman J, Hochhaus A, Simonsson B, Appelbaum F, et al. Evolving concepts in the management of chronic myeloid leukemia: recommendations from an expert panel on behalf of the European LeukemiaNet. Blood. September. 15. 2006;108(6):1809-1820. [pmid: 16709930].
125 Ernst T, Erben P, Muller MC, Paschka P, Schenk T, Hoffmann J, et al. Dynamics of BCR-ABL mutated clones prior to hematologic or cytogenetic resistance to imatinib.[see comment]. Haematologica. February. 2008;93(2):186-192. [pmid: 18223278].
126 Marin D, Kaeda JS, Andreasson C, Saunders SM, Bua M, Olavarria E, et al. Phase I/II trial of adding semisynthetic homoharringtonine in chronic myeloid leukemia patients who have achieved partial or complete cytogenetic response on imatinib. Cancer. May. 1. 2005;103(9):1850-1855. [pmid: 15786422].
127 Willis SG, Lange T, Demehri S, Otto S, Crossman L, Niederwieser D, et al. High-sensitivity detection of BCR-ABL kinase domain mutations in imatinib-naive patients: correlation with clonal cytogenetic evolution but not response to therapy. Blood. September. 15. 2005;106(6):2128-2137. [pmid: 15914554].
128 Quintas-Cardama A, Cortes JE, O'Brien S, Ravandi F, Borthakur G, Liu D, et al. Dasatinib early intervention after cytogenetic or hematologic resistance to imatinib in patients with chronic myeloid leukemia. Cancer. July. 1. 2009;115(13):2912-2921. [pmid: 19402171].
129 Kantarjian H, Pasquini R, Hamerschlak N, Rousselot P, Holowiecki J, Jootar S, et al. Dasatinib or high-dose imatinib for chronic-phase chronic myeloid leukemia after failure of first-line imatinib: a randomized phase 2 trial. Blood. June. 15. 2007;109(12):5143-5150. [pmid: 17317857].
130 Kantarjian H, Sawyers C, Hochhaus A, Guilhot F, Schiffer C, Gambacorti-Passerini C, et al. Hematologic and cytogenetic responses to imatinib mesylate in chronic myelogenous leukemia. N Engl J Med. February. 28. 2002;346(9):645-652. [pmid: 11870241].
131 Jabbour E, Kantarjian HM, Jones D, Shan J, O'Brien S, Reddy N, et al. Imatinib mesylate dose escalation is associated with durable responses in patients with chronic myeloid leukemia after cytogenetic failure on standard-dose imatinib therapy. Blood. March. 5. 2009;113(10):2154-2160. [pmid: 19060245].
132 Cortes J, Quintas-Cardama A, Garcia-Manero G, O'Brien S, Jones D, Faderl S, et al. Phase 1 study of tipifarnib in combination with imatinib for patients with chronic myelogenous leukemia in chronic phase after imatinib failure. Cancer. November. 1. 2007;110(9):2000-2006. [pmid: 17849425].
133 Oki Y, Kantarjian HM, Gharibyan V, Jones D, O'Brien S, Verstovsek S, et al. Phase II study of low-dose decitabine in combination with imatinib mesylate in patients with accelerated or myeloid blastic phase of chronic myelogenous leukemia. Cancer. March. 1. 2007;109(5):899-906. [pmid: 17236224].
134 Cortes J, Jabbour E, Daley GQ, O'Brien S, Verstovsek S, Ferrajoli A, et al. Phase 1 study of lonafarnib (SCH 66336) and imatinib mesylate in patients with chronic myeloid leukemia who have failed prior single-agent therapy with imatinib. Cancer. September. 15. 2007;110(6):1295-1302. [pmid: 17623836].
135 Shah NP, Kantarjian HM, Kim DW, Rea D, Dorlhiac-Llacer PE, Milone JH, et al. Intermittent target inhibition with dasatinib 100 mg once daily preserves efficacy and improves tolerability in imatinib-resistant and -intolerant chronic-phase chronic myeloid leukemia. Journal of Clinical Oncology. July. 1. 2008;26(19):3204-3212. [pmid: 18541900].
136 Hochhaus A, Baccarani M, Deininger M, Apperley JF, Lipton JH, Goldberg SL, et al. Dasatinib induces durable cytogenetic responses in patients with chronic myelogenous leukemia in chronic phase with resistance or intolerance to imatinib. Leukemia. June. 2008;22(6):1200-1206. [pmid: 18401416].
137 Hochhaus A, Kantarjian HM, Baccarani M, Lipton JH, Apperley JF, Druker BJ, et al. Dasatinib induces notable hematologic and cytogenetic responses in chronic-phase chronic myeloid leukemia after failure of imatinib therapy.[erratum appears in Blood. 2007 Sep 1;110(5)1438]. Blood. March. 15. 2007;109(6):2303-2309. [pmid: 17138817].
138 Kantarjian H, Cortes J, Kim DW, Dorlhiac-Llacer P, Pasquini R, DiPersio J, et al. Phase 3 study of dasatinib 140 mg once daily versus 70 mg twice daily in patients with chronic myeloid leukemia in accelerated phase resistant or intolerant to imatinib: 15-month median follow-up. Blood. June. 18. 2009;113(25):6322-6329. [pmid: 19369231].
139 Guilhot F, Apperley J, Kim DW, Bullorsky EO, Baccarani M, Roboz GJ, et al. Dasatinib induces significant hematologic and cytogenetic responses in patients with imatinib-resistant or -intolerant chronic myeloid leukemia in accelerated phase. Blood. May. 15. 2007;109(10):4143-4150. [pmid: 17264298].
140 Cortes J, Kim DW, Raffoux E, Martinelli G, Ritchie E, Roy L, et al. Efficacy and safety of dasatinib in imatinib-resistant or -intolerant patients with chronic myeloid leukemia in blast phase. Leukemia. December. 2008;22(12):2176-2183. [pmid: 18754032].
141 Cortes J, Rousselot P, Kim DW, Ritchie E, Hamerschlak N, Coutre S, et al. Dasatinib induces complete hematologic and cytogenetic responses in patients with imatinib-resistant or -intolerant chronic myeloid leukemia in blast crisis. Blood. April. 15. 2007;109(8):3207-3213. [pmid: 17185463].
142 Talpaz M, Shah NP, Kantarjian H, Donato N, Nicoll J, Paquette R, et al. Dasatinib in imatinib-resistant Philadelphia chromosome-positive leukemias.[see comment]. New England Journal of Medicine. June. 15. 2006;354(24):2531-2541. [pmid: 16775234].
143 Sakamaki H, Ishizawa K, Taniwaki M, Fujisawa S, Morishima Y, Tobinai K, et al. Phase 1/2 clinical study of dasatinib in Japanese patients with chronic myeloid leukemia or Philadelphia chromosome-positive acute lymphoblastic leukemia. International Journal of Hematology. April. 2009;89(3):332-341. [pmid: 19263190].
144 Wu J, Meng F, Kong LY, Peng Z, Ying Y, Bornmann WG, et al. Association between imatinib-resistant BCR-ABL mutation-negative leukemia and persistent activation of LYN kinase.[see comment]. Journal of the National Cancer Institute. July. 2. 2008;100(13):926-939. [pmid: 18577747].
145 Kantarjian HM, Giles F, Gattermann N, Bhalla K, Alimena G, Palandri F, et al. Nilotinib (formerly AMN107), a highly selective BCR-ABL tyrosine kinase inhibitor, is effective in patients with Philadelphia chromosome-positive chronic myelogenous leukemia in chronic phase following imatinib resistance and intolerance. Blood. November. 15. 2007;110(10):3540-3546. [pmid: 17715389].
146 le CP, Ottmann OG, Giles F, Kim DW, Cortes J, Gattermann N, et al. Nilotinib (formerly AMN107), a highly selective BCR-ABL tyrosine kinase inhibitor, is active in patients with imatinib-resistant or -intolerant accelerated-phase chronic myelogenous leukemia. Blood. February. 15. 2008;111(4):1834-1839. [pmid: 18048643].
147 Kantarjian H, Giles F, Wunderle L, Bhalla K, O'Brien S, Wassmann B, et al. Nilotinib in imatinib-resistant CML and Philadelphia chromosome-positive ALL.[see comment]. New England Journal of Medicine. June. 15. 2006;354(24):2542-2551. [pmid: 16775235].
148 Cortes J, Jabbour E, Kantarjian H, Yin CC, Shan J, O'Brien S, et al. Dynamics of BCR-ABL kinase domain mutations in chronic myeloid leukemia after sequential treatment with multiple tyrosine kinase inhibitors. Blood. December. 1. 2007;110(12):4005-4011. [pmid: 17785585].
149 Quintas-Cardama A, Kantarjian H, Jones D, Nicaise C, O'Brien S, Giles F, et al. Dasatinib (BMS-354825) is active in Philadelphia chromosome-positive chronic myelogenous leukemia after imatinib and nilotinib (AMN107) therapy failure. Blood. January. 15. 2007;109(2):497-499. [pmid: 16990591].
150 Khorashad JS, de LH, Apperley JF, Milojkovic D, Reid AG, Bua M, et al. Finding of kinase domain mutations in patients with chronic phase chronic myeloid leukemia responding to imatinib may identify those at high risk of disease progression. Journal of Clinical Oncology. October. 10. 2008;26(29):4806-4813. [pmid: 18645191].
151 de LH, Apperley JF, Khorashad JS, Milojkovic D, Reid AG, Bua M, et al. Imatinib for newly diagnosed patients with chronic myeloid leukemia: incidence of sustained responses in an intention-to-treat analysis.[see comment]. Journal of Clinical Oncology. July. 10. 2008;26(20):3358-3363. [pmid: 18519952].
152 Marin D, Khorashad JS, Foroni L, Milojkovic D, Szydlo R, Reid AG, et al. Does a rise in the BCR-ABL1 transcript level identify chronic phase CML patients responding to imatinib who have a high risk of cytogenetic relapse?. British Journal of Haematology. May. 2009;145(3):373-375. [pmid: 19344397].
153 Branford S, Rudzki Z, Walsh S, Parkinson I, Grigg A, Szer J, et al. Detection of BCR-ABL mutations in patients with CML treated with imatinib is virtually always accompanied by clinical resistance, and mutations in the ATP phosphate-binding loop (P-loop) are associated with a poor prognosis. Blood. July. 1. 2003;102(1):276-283. [pmid: 12623848].
154 Wei Y, Hardling M, Olsson B, Hezaveh R, Ricksten A, Stockelberg D, et al. Not all imatinib resistance in CML are BCR-ABL kinase domain mutations. Annals of Hematology. December. 2006;85(12):841-847. [pmid: 17006667].
155 Hughes TP, Branford S, White DL, Reynolds J, Koelmeyer R, Seymour JF, et al. Impact of early dose intensity on cytogenetic and molecular responses in chronic- phase CML patients receiving 600 mg/day of imatinib as initial therapy. Blood. November. 15. 2008;112(10):3965-3973. [pmid: 18768781].
156 Chu S, Xu H, Shah NP, Snyder DS, Forman SJ, Sawyers CL, et al. Detection of BCR-ABL kinase mutations in CD34+ cells from chronic myelogenous leukemia patients in complete cytogenetic remission on imatinib mesylate treatment.[see comment]. Blood. March. 1. 2005;105(5):2093-2098. [pmid: 15345592].
157 Castaldi PJ, Cho MH, Cohn M, Langerman F, Moran S, Tarragona N, et al. The COPD genetic association compendium: a comprehensive online database of COPD genetic associations. Hum Mol Genet. 2009. December. 2.
158 Ioannidis JP, Trikalinos TA, Khoury MJ. Implications of small effect sizes of individual genetic variants on the design and interpretation of genetic association studies of complex diseases. Am J Epidemiol. October. 1. 2006;164(7):609-614. [pmid: 16893921].