# Summary

Microscopic (pathologic) analysis of tissue samples is central to the diagnosis and management of patients with malignancy. There are several instances where the morphologic analysis of a tissue specimen is inconclusive and may not be able to inform management decisions (e.g., trying to distinguish a metastatic tumor from a de novo primary tumor), or in some instances trying to distinguish malignant from nonmalignant tissue (e.g., sorting apart glial neoplasms from reactive gliosis).

Topographic genotyping integrates anatomic pathology and molecular analyses. Briefly, it involves performing microscopic examination of a specimen, identifying areas of interest on the pathology slide, and microdissecting (manually excising) them under the microscope. The minute tissue samples, enriched in tumor cells, can be subjected to molecular analyses with specifically developed protocols.

It has been claimed that analyzing microdissected tissue areas using specific genetic marker panels can aid pathologic diagnosis, individualize prognosis and guide treatment decisions. Herein we perform a systematic review of the published literature on loss-of-heterozygosity based topographic genotyping with PathfinderTG®, a patented technology for topographic genotyping offered by the private company RedPath Integrated Pathology Inc. (www.redpathip.com).

## Methods

The following key questions were asked:

1. What is the published evidence on the analytic test performance (analytic sensitivity and specificity) of loss-of-heterozygosity based topographic genotyping with PathfinderTG® compared to a gold standard test (Fryback Level 1)?
2. What is the published evidence on the diagnostic ability and clinical validity of loss-of-heterozygosity based topographic genotyping with PathfinderTG® (Fryback Levels 2, 3, 4 and 5)?
3. What is the direct evidence comparing loss-of-heterozygosity based topographic genotyping with PathfinderTG® with conventional pathology without this process for clinical outcomes?
4. Does the study indicate whether informed consent was given, whether Institutional Review Board (IRB) approval was obtained, and whether institutional guidelines for human subject protection were considered in the design or implementation of the study,
5. For published studies of loss-of-heterozygosity based topographic genotyping with PathfinderTG® does the study indicate how the study population relates to the Medicare beneficiary population (for example, by providing an age or age-group breakdown or profile of the study population)?

Eligible were only studies evaluating the patented technology, and more specifically, those using loss of heterozygosity (LOH) analysis. In addition, eligible studies on analytic validity and on diagnostic and predictive ability were required to have a suitable reference standard. We excluded studies with less than 10 patients, studies that did not use LOH analyses on microdissected samples, and studies that described molecular differences of different tumor subgroups without quantifying the diagnostic or prognostic ability of loss-of-heterozygosity based topographic genotyping with PathfinderTG® (as an overall diagnostic process) against a suitable reference standard.

## Results

### Key Question 1

We did not identify any studies on the analytic validity of loss-of-heterozygosity based topographic genotyping with PathfinderTG®. The laboratory that performs these analyses is CLIA (Clinical Laboratory Improvement Amendments) and New York State certified and College of American pathologists accredited to perform high complexity analyses. The data from these certifications and accreditations are generally not publicly available.

### Key Question 2

We identified 15 eligible publications. These pertained to lung cancer (n=4), pancreatic and biliary tree tumors (n=4), hepatocellular carcinoma (n=4), gliomas, thyroid tumors, lacrimal gland tumors and mucinous tumors of the appendix (n=1 for each). Sample sizes ranged from 11 to 103.

Microdissection and molecular analysis protocols were described in detail in all studies. However, details on patient (sample) selection, patient characteristics, treatments received, clinical endpoint definitions, justification of sample size, selection of classification thresholds (for molecular analysis aggregate scores such as fractional allelic loss (FAL)), selection among various statistical models, and other important parameters of study design and reporting were provided inconsistently.

All studies were retrospective in design and used available archival tissue blocks. In a single study, molecular profiles of gliomas and reactive gliosis were determined retrospectively, and then they were used prospectively on 16 diagnostically challenging cases of reactive gliosis versus glial tumors.

Three publications pertained to diagnostic accuracy: Two examined the ability of loss-of-heterozygosity based topographic genotyping with PathfinderTG® to diagnose malignancy from pancreatico-biliary cytology specimens, and one its ability to diagnose reactive gliosis versus glioma. The reference standard was pathological confirmation of surgical specimens or long-term clinical followup, as applicable.

The remaining 10 publications evaluated the association of loss-of-heterozygosity based topographic genotyping with PathfinderTG® aggregate scores and survival, recurrence-free survival, and tumor recurrence. Retrospectively collected clinical data were used to ascertain outcomes. Overall, studies used different and arbitrary cutoffs in the FAL to classify studies, did not adjust for treatment or other predictors of outcome and did not provide multivariate analyses. In seven out of 10 publications FAL was identified as a statistically significant predictor of a clinical outcome in at least one analysis or subgroup (and for the presented cutoffs).

### Key Question 3

We did not identify any eligible studies.

### Key Question 4

All studies except for two specifically mentioned that IRB approval was obtained. However, during the peer review period, the company clarified that all studies were conducted following institutional mandates.

### Key Question 5

No study explicitly stated its applicability to the Medicare beneficiary population. Five studies did not provide any information on age distributions. In the remaining eight studies, mean ages ranged from 48 to 70 years (above 60 years in six studies).

## Overview

Most studies of loss-of-heterozygosity based topographic genotyping with PathfinderTG® were excluded because they only described the molecular profile of different tumors, without assessing the ability of the method to help improve making diagnosis or prognosis. There were no studies that directly inform on the effect of using loss-of-heterozygosity based topographic genotyping with PathfinderTG® on patient-relevant clinical outcomes. Eligible studies on the diagnostic and prognostic ability of loss-of-heterozygosity based topographic genotyping with PathfinderTG® were small in sample size, had overt methodological limitations, and did not clearly report important characteristics of their study design. Most studies clearly reported receiving IRB approval. Evaluating the applicability of studies to the Medicare beneficiary population was hindered by the lack of details on patient characteristics.

### Introduction

Microscopic analysis of tissue samples is central to the diagnosis and management of patients with malignancy. There are several instances where the morphologic analysis of a tissue specimen is inconclusive and may not be able to inform management decisions. For example, two morphologically similar tumors in the same patient may or may not have arisen from the same tumor (i.e., one tumor may be a de novo independent tumor from the already diagnosed tumor),1 or in some instances where it is difficult to distinguish malignant from nonmalignant tissue (e.g., some glial neoplasms from reactive gliosis2).

Molecular testing in anatomic pathology has emerged as a means to address many difficulties in the diagnosis of disease. Some researchers have also advocated that it can provide better prognosis and facilitate treatment guidance.

One of the technical difficulties of molecular testing in anatomic pathology stems from the fact that tumors are heterogeneous, i.e., tumor tissues from a pathological specimen contain various subpopulations of cells. Methods such as flow cytometry can separate cellular subpopulations based on their phenotypes, but they do not allow for concurrent microscopy analyses, and they typically require large quantities of fresh tissues.3 An alternative approach is to perform microscopic examination of a specimen, identify areas of interest on the pathology slide, and to microdissect (manually excise) them under the microscope. This will allow one to obtain minute tissue samples that are enriched in tumor cells and can be used for molecular analyses with specifically developed protocols.

It has been claimed that analyzing microdissected tissue areas using specific genetic marker panels –topographic genotyping– can aid pathologic diagnosis, individualize prognosis and guide treatment decisions. Herein we perform a systematic review of the published literature on loss-of-heterozygosity based topographic genotyping with PathfinderTG®, a patented technology for topographic genotyping offered by the private company RedPath Integrated Pathology Inc. (www.redpathip.com).

The aim of the systematic review is to describe the published evidence on the analytic validity of loss-of-heterozygosity based topographic genotyping with PathfinderTG®, as well as the published evidence on its clinical validity and utility.

### Methods

This Technology Assessment focuses specifically on the patented RedPath PathfinderTG® technology, namely loss-of-heterozygosity based topographic genotyping with. In discussions with the cofounder and Chief Scientific Officer of RedPath, Dr. Sydney Finkelstein, it was clarified that only papers (co)authored by Dr. Finkelstein have used the patented technology (see below for a description). Therefore, only published English-language studies in which Dr Sydney Finkelstein is among the authors were eligible for the Technology Assessment.

The Technology Assessment follows the Fryback and Thornbury framework for assessing studies that evaluate diagnostic tests.4 The framework distinguishes six levels for the evaluation of diagnostic technologies.

1. Technical feasibility and optimization
2. Diagnosis (i.e., diagnostic accuracy, or prognostic accuracy)
3. Impact on diagnostic thinking (e.g., ordering new tests)
4. Impact on therapeutic choices (e.g., choosing a treatment over another)
5. Impact on patient outcomes (e.g., in a clinical trial)
6. Societal impact (e.g., a cost-effectiveness analysis)

The framework was developed for imaging tests, and does not necessarily apply equally well to the evaluation of PathfinderTG®. However, the rationale of the framework is generic, and we were able to use it by applying lenient criteria to assign identified studies to levels in the framework.

## Task order

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested an assessment on the use of PathfinderTG® (a patented technology) for disease diagnosis and prediction of clinical outcomes from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the Tufts Evidence-based Practice Center: (Contract No. HHSA 290 2007 10055 I). After discussions with AHRQ and CMS and after exploration of the literature, five key questions were formulated (see next paragraph).

## Key questions

### Key question 1 What is the published evidence on the analytic test performance (analytic sensitivity and specificity) of PathfinderTG® compared to a gold standard test (Fryback Level 1)?

This key question pertains both to the microdissection and to the molecular analytic stage (specifically LOH analysis) of loss-of-heterozygosity based topographic genotyping with PathfinderTG®. (See definition of LOH in later part of this section.)

More specifically, there are 3 subquestions:

Subquestion 1.1: What is the test performance (sensitivity and specificity) of loss-of-heterozygosity based topographic genotyping with PathfinderTG® compared with “gold standard” tests for the detection or quantitation of genetic characteristics of a specimen?

a. Document potential bias or potential technical limitations in loss-of-heterozygosity based topographic genotyping with PathfinderTG® diagnostic testing methods.
b. Describe the “gold standard” used to determine that one or more genetic characteristic(s) is (are) present or not. Are there published reviews of the used “gold standard” test method, its limitations if any? Describe the population(s) in which the gold standard can be reliably used to detect or quantify a genetic characteristic, disease, or condition.

Subquestion 1.2: Are there published studies on the reliability (repeatability and reproducibility) of the assessment of loss-of-heterozygosity based topographic genotyping with PathfinderTG® results?

Subquestion 1.3: If an algorithm, decision tree, calculation, or other interpretation procedure is used in assessing loss-of-heterozygosity based topographic genotyping with PathfinderTG® results:

c. Are there published studies about how the algorithm, decision tree, or other interpretation procedure was developed?
d. Are there published studies about how the algorithm, decision tree, or other interpretation procedure was validated in a previously untested population?
e. Are there published studies about how the algorithm, decision tree, or other interpretation procedure compared to reference standard diagnostic studies used for the same purpose (e.g., panel of tumor markers for prognosis)?

### Key question 2 What is the published evidence on the diagnostic ability and clinical validity of loss-of-heterozygosity based topographic genotyping with PathfinderTG® (Fryback Levels 2, 3, 4 and 5)?

Diagnostic ability (Fryback Level 2) pertains to the sensitivity and specificity of loss-of-heterozygosity based topographic genotyping with PathfinderTG® to diagnose a disease as ascertained by a reference standard. Clinical validity is the ability to affect patient outcomes. Here it is considered as Levels 3 to 5 in the Fryback framework, that is, the ability to impact on diagnostic thinking (Level 3, e.g., number of times a diagnosis changed after the examined diagnostic process was implemented), impact on therapeutic decision (Level 4, e.g., number of times patient management changed after loss-of-heterozygosity based topographic genotyping with PathfinderTG® was implemented), and the ability to affect patient outcomes (Level 5, e.g., changes in patient-relevant clinical outcomes when loss-of-heterozygosity based topographic genotyping with PathfinderTG® testing was implemented).

### Key question 3 What is the direct evidence comparing loss-of-heterozygosity based topographic genotyping with PathfinderTG® with conventional pathology without PathfinderTG® for clinical outcomes?

This key question focuses on comparative studies (of using versus not using loss-of-heterozygosity based topographic genotyping with PathfinderTG®) for patient-relevant clinical outcomes. Such studies fall into Level 5 in the Fryback classification.

### Key question 4 For published studies of loss-of-heterozygosity based topographic genotyping with PathfinderTG® involving human subjects, does the study indicate whether

a. Informed consent was given by subjects participating in the evaluation of loss-of-heterozygosity based topographic genotyping with PathfinderTG® diagnostic techniques?
b. IRB approval was needed for the study?
c. Institutional guidelines for human subject protection were considered in the design or implementation of the study?

In discussions with CMS and AHRQ, it was decided to examine this key question for studies eligible for key questions 1 to 3.

### Key question 5 For published studies of loss-of-heterozygosity based topographic genotyping with PathfinderTG®, does the study indicate how the study population relates to the Medicare beneficiary population (for example, by providing an age or age-group breakdown or profile of the study population)?

In discussions with CMS and AHRQ, it was decided to examine this key question for studies eligible for key questions 1 to 3.

## Eligibility criteria

### General criteria

#### Inclusion criteria

Eligible were only studies fulfilling the following criteria:

1. Evaluating the patented loss-of-heterozygosity based topographic genotyping with PathfinderTG® technology.
  As mentioned above, in communications with the company and its Chief Scientific Officer, it was clarified that Dr. Sydney Finkelstein would be an author or coauthor of all such papers.
2. Using loss of heterozygosity (LOH) analysis on microdissected samples.
  For example, we excluded studies that performed LOH analyses on DNA extracted from pancreatic cyst fluid by means of column separation (without using microdissection to isolate cells from the cystic fluid).
  The performance of loss-of-heterozygosity based topographic genotyping with PathfinderTG® as a diagnostic or prognostic tool depends also on the typed genetic marker panels. Since the focus of this Technology Assessment is on LOH-based analyses, we did not consider studies that focused only on the detection of mutations of K-ras-2 or P53 (unless they also included a panel of microsatellite markers and provided a single “aggregate” score/risk/disposition per patient – see below). Furthermore, the majority of papers examining the prognostic and diagnostic ability of mutations in the P53 and K-ras-2 genes in cancer are not included in our Technology Assessment (because Dr. Finkelstein is not among the authors – an operational criterion to identify studies that use the patented technology).
3. At least 10 analyzed patients.

#### Exclusion criteria

We excluded studies that described molecular differences of different tumor subgroups without quantifying the diagnostic or prognostic ability of loss-of-heterozygosity based topographic genotyping with PathfinderTG® (as an overall test) against a suitable reference standard.

### Specific criteria for Key Questions 1 and 2

In addition, after discussions with AHRQ and CMS, the following eligibility criteria were set for Key Questions 1 and 2:

For Key Question 1:

1. Experimental studies that can quantify the analytic sensitivity and the analytic specificity of loss-of-heterozygosity based topographic genotyping with PathfinderTG® to detect LOH in samples in which known LOH state was based on a reference method.
2. The design of the study should be such that it controls for the effect of potential confounders (e.g., within-tissue heterogeneity).
3. The reference method would preferably be Copy Number Variation (CNV) analysis,5 or any other reference method chosen by the authors.

Eligible for Key Question 2 were single arm noncomparative studies (N>=10) or comparative studies (comparing using loss-of-heterozygosity based topographic genotyping with PathfinderTG® versus not) for diagnosis, prognosis or treatment guidance.

We excluded studies that only described the molecular profile of tumors without evaluating the accuracy of loss-of-heterozygosity based topographic genotyping with PathfinderTG® diagnosis or risk stratification against a reference standard. For example, studies on diagnostically challenging tumors are excluded, unless they have data from long enough clinical followup. Similarly, studies on inconclusive cytology specimens are excluded, unless they are verified against surgical biopsy, adequate clinical followup or other extensive workup.

Finally, we excluded studies that did not use any LOH analyses; and studies that did not use an aggregate score for all genetic markers, but instead described each molecular marker separately. An aggregate score could be anything that integrates information from the whole loss-of-heterozygosity based topographic genotyping with PathfinderTG® diagnostic process, either by simply using the proportion of markers exhibiting LOH, or using more sophisticated approaches (e.g., artificial neural networks, or other classifiers).

## Terminology and definitions

### Microdissection

Microdissection (Figure 1) is the process of extracting a microscopic tissue area from a tissue sample, typically from a pathology slide. By extension, it is the selection of a subset of cells from a brush cytology specimen. Microdissection can be manual, or laser assisted.

First, the specialist (pathologist) selects tissue areas with high purity of tumor cells on a tissue slide. Manual microdissection is based on the fact that dry and wet tissue on a pathology slide separate cleanly: The area of interest is first dampened slightly with a small amount of buffer solution and then scraped off with the edge of a scalpel under stereomicroscopic^a^ visualization.3

a It is possible to use an ordinary microscope also. However, the image in the ordinary microscope is inverted and for some magnifications the distance between the microscope lens and the glass slide is too small to allow for easy microdissection.3

In laser microdissection, the specialist uses a laser beam to separate individual cells from the adjacent tissues. Different systems for laser microdissection exist. One system uses lasers to attach individual cells on a special thermoplastic membrane overlaid on the tissue slide. When the membrane is lifted from the tissue, the selected cells remain attached to it and are effectively “microdissected”. Other systems use the laser beam to “cut” the area of interest from the surrounding tissue, so that it will fall off by gravity. Laser microdissection is reported as accurate enough to extract individual cells from a tissue slide.3

Finally, there are other microdissection methods that have been described,3 including methods that use craft glue,6 or tissue glue7 that adheres on the area of interest, and detaches it (the area of interest) from the slide when it is “peeled” off.

Figure 1 Manual microdissection of a small tumor area from a pathology slide

Example of microdissection of two small tumor areas.8 The left photograph shows two minute pulmonary meningothelial-like nodules (small nodules in the lung) stained with hematoxylin and eosin (a “scout” section3 to guide the microdissection of the unstained tissue on the right); the right photograph is an unstained adjacent tissue slide after the manual microdissection of the areas corresponding to the two nodules.

(Reproduced with permission from lonescu D et al. Am J Surg Pathol. 2004;28:207–14, Figure 1)

Figure 1 is two adjacent photographs, which show an example of microdissection of two small tumor areas. The left photograph shows two minute pulmonary meningothelial-like nodules (small nodules in the lung) stained with hematoxylin and eosin (a “scout” section3 to guide the microdissection of the unstained tissue on the right); the right photograph is an unstained adjacent tissue slide after the manual microdissection of the areas corresponding to the two nodules. (This image was reproduced with permission from Ionescu D et al. Am J Surg Pathol. 2004;28:207–14, Figure 1)

### Topographic genotyping

Topographic genotyping integrates microscopic analysis and microdissection with genomic mutational profiling of the microdissected areas.

The microdissected tissue areas are enriched in tumor cells. The DNA extracted from these samples is therefore not greatly contaminated by DNA from nonmalignant cells (e.g., from supporting stromal cells). Genetic (molecular) analyses of the microdissected samples can provide a molecular profile of malignant cells, i.e., they inform on the presence or absence of selected genetic variations in malignant cells.

This combination of microdissection and genetic analyses on the extracted tumor areas has been used by several researchers and is not a unique characteristic of the PathfinderTG® diagnostic process.

### PathfinderTG®

PathfinderTG® is a patented technology for topographic genotyping and other molecular analyses. The patented technology pertains to the ability for enhanced amplification of genetic material from minute tissue samples, even from archival blocks of fixative-treated samples or unstained pathology slides.

### Microsatellite markers

Microsatellites are a type of common variation in the genetic material. Other types of genetic variations include single nucleotide polymorphisms (SNPs) and insertions/deletions (Ins/Del).

Microsatellites are short repeated DNA sequences that are found in various loci throughout the human genome. Examples of such repeats are TATA… TA, n times [commonly denoted as (TA)n]. Different “alleles” of a specific microsatellite marker essentially differ in the number of repeats, n. Microsatellite markers are highly polymorphic, because n can range between 4 and 40 for many markers. Especially for this reason (their high polymorphism), they are often used as markers in genetic analyses.

In contrast, SNPs are common single-base changes in specific locations in the genome. A SNP is a biallelic marker (the two alleles are the bases that change).

### Loss of heterozygosity (LOH)

Cellular DNA is constantly damaged and repaired. Generally speaking, cancers can arise when excessive DNA alterations accumulate beyond the restoration capacity of repair mechanisms. Loss of heterozygosity (LOH) can be a telltale sign that DNA repair mechanisms (homologous recombination in particular –see below) have acted in specific regions in the DNA.

LOH is a frequent genetic alteration in many neoplasms.9 It is theorized that LOH alterations that co-locate in specific genomic regions (e.g., near genes implicated in the pathogenesis of malignancy) may have prognostic significance (they imply DNA repair activity near these genes).9 In addition, observing increased rates of LOH is considered an indication of inactivation of tumor suppressor genes. Most often, LOH is evaluated for microsatellite markers.

#### Homologous recombination and LOH

In our somatic cells we have two chromosomal homologues (two “copies” of each DNA macromolecule). When either one of them is damaged, the cell repairs it using several mechanisms. Homologous recombination (or general recombination) is one DNA repair mechanism that corrects the damaged chromosomal homologue using the other as a template. Homologous recombination corrects many DNA repair problems, but can introduce changes to the DNA. Assuming that the two chromosomal homologues differ at (or very near) a DNA site that has been damaged (i.e., the person is heterozygous at that position), homologous recombination will make both chromosomal analogues homozygous (identical) at the repaired site and near it, because it uses one DNA strand as the template to correct the other. Effectively, there is a loss of heterozygosity. It is well appreciated that excessive homologous recombination can lead to malignancies because of increased loss of heterozygosity.10

### Fractional allelic loss (FAL)

FAL is the proportion of informative (heterozygous) microsatellites that exhibit LOH. It is a simple aggregate score. Other methods of obtaining a diagnostic or prognostic score (information) of a panel of markers exist (e.g., with neural networks, logistic regression, support vector machines or other techniques).