# Results

## Eligible studies

We examined 155 papers in which Dr Finkelstein was among the co-authors in full text. According to the pre-specified criteria, 15 reports were eligible for this Technology Assessment.

## Key Question 1 What is the published evidence on the analytic test performance (analytic sensitivity and specificity) of loss-of-heterozygosity based topographic genotyping with PathfinderTG® compared to a gold standard test (Fryback Level 1)?

None of the included studies evaluated the analytic validity of microdissection or LOH analyses in the PathfinderTG® framework compared to a reference standard.

### Subquestion 1.1

We did not find data informing on the sensitivity and specificity of the microdissection or the LOH-based molecular analysis component of PathfinderTG® among the eligible papers.

The laboratory that performs these analyses is CLIA (Clinical Laboratory Improvement Amendments) and New York State certified and College of American pathologists accredited to perform high complexity analyses. The data from these certifications and accreditations are generally not publicly available.

#### Subquestions 1.1(a) and (b)

The authors made the following comments and clarifications:

- The authors of the papers reviewed noted that manual microdissection was successful in obtaining tissue slide areas with sufficient purity in tumor cells to allow for successful topographic genotyping.
- The authors of the paper reviewed reported following protocols developed to avoid the phenomenon of allelic dropout (ADO) during LOH analyses. ADO can occur during PCR amplification, when nucleic acid amplification preferentially favors one allelic DNA template over the other, because of limiting quantities of starting DNA in the microdissected samples.11,12 The phenomenon was originally described in the context of single-cell PCR, but has been described in situations where genotyping is performed on biopsy samples of fixed tissue specimens.13 The authors reported avoiding ADO by microdissecting equally-sized tumor and normal tissue areas for LOH analyses.

### Subquestion 1.2

There were no eligible studies on the test-retest repeatability and reproducibility of results (either within batch or between runs repeatability, or on test reproducibility across laboratories).

### Subquestion 1.3

Regarding the development of algorithms and interpretation procedures in the assessment of PathfinderTG® results, please refer to Key Question 2.

## Key Question 2 What is the published evidence on the diagnostic ability and clinical validity of loss-of-heterozygosity based topographic genotyping with PathfinderTG® (Fryback Levels 2, 3, 4 and 5)?

We identified 15 eligible publications. These pertained to lung cancer (n=4),14–17 pancreatic and biliary tree tumors (n=4),18–21 hepatocellular carcinoma (n=3),1,22,23 gliomas,2 thyroid tumors,24 lacrimal gland tumors25 and mucinous tumors of the appendix26 (n=1 for each).

### Characteristics of study design

All studies were retrospective in design and used convenience sampling, namely archival tissue blocks that were available. It is unknown how many patients with similar clinical status for whom samples were not available, and whether they had systematically different characteristics from those analyzed (sampling bias). The authors did not report efforts to correct for sampling bias in any study.

In a single study, molecular profiles of gliomas and reactive gliosis were determined retrospectively, and then they were used prospectively on 16 diagnostically challenging cases of reactive gliosis versus glial tumors.2

Sample sizes ranged from 11 to 103 patients, with only three publications reporting on more than 50 patients.1,22,23 It is possible that these three publications analyzed the same patient population (patients with hepatocellular carcinomas) with different methods.

### Characteristics of included patients

All study populations were convenience samples. With one exception,2 all studies included only archival tissue samples that were available for analyses.

As shown in Table 1a, 1b and 1c, most studies did not describe patient characteristics in detail. For example, basic information on age (mean or median age and standard deviation or range) was not given in seven of 15 studies.1,2,19,21–23,25 Five studies reported no information on patients’ treatments.

Table 1a Characteristics of patients with gastrointestinal tumors in the included studies

Author Year [PMID] | N | Description | Histology and stage | Age | Treatments
Cong 2001 [11260864] | 22 | Paraffin blocks from surgical resections of CC (1989–1999); no prior chemo- or radiotherapy | CC T: 1–3 N: 0–2 M: nd | Mean age 63 y; 11/22 (50%) ≥ age 65 | Surgery^b^; b No details reported regarding surgical treatment and adjuvant chemo- or radiotherapy.
Finkelstein 2003 [12668980] | 103 | Paraffin blocks from primary HCC (1988–1996); hepatic transplant recipients with > 5 y follow-up | HCC | Not stated | Hepatic transplant
Marsh 2003 [12827550] | 103 | Paraffin blocks from primary HCC^c^; c Primary diagnosis: hepatitis C (n=30), hepatitis B (n=24), cryptogenic cirrhosis (n=16), alcoholic hepatitis (n=13), hemochromatosis (n=4), alpha-1 antitrypsin deficiency (n=2), primary biliary cirrhosis (n=2), autoimmune hepatitis (n=1),primary sclerosing cholangitis (n=1); (1988–1996); hepatic transplant recipients with > 5 y follow-up | HCC | Not stated | Hepatic transplant
Khalid 2004 [15542529] | 26 | Papanicolaou-stained smears of pancreatico-biliary brush cytology^d^; d DNAs from paraffin blocks from surgical resections were also evaluated.; of patients suspected of having malignancy (inferred) | PDC (n=6) CC (n=11) Inflammatory (n=9) | Not stated | NA
Khalid 2006 [17029619] | 21 | Papanicolaou-stained smears of pancreatico-biliary cytology obtained by EUS-FNA‡ of patients suspected of having malignancy (inferred); either positive or inconclusive cytology cases only | PDC (n=15) ACC (n=1) CC (n=1) AIP/PIN (n=1) CP (n=2) AIP (n=3) | Mean age 66 y; 12/2 (57%) ≥ age 65 | NA
Schwartz 2008 [18602719] | 70 | Archival tissue from consecutive patients after liver transplantation for HCC (35 fulfilling Milan criteria, 35 beyond)^e^; e Based on histology only. | HCC | Mean age 55.3, (SD = 10.4) | Hepatic transplant
Fasanella 2009 [19152901] | 29^f^; f 27 and 25 reported in tables and figures, depending on outcome described | Patients with pancreatic endocrine tumors (PET) with molecular analyses. Excluded were patients with other malignancies or stable disease with <1 year follow up. | Pancreatic endocrine tumors (PET) | 57 (range 31–80) | Surgery in 23/29

ACC: acinar cell carcinoma; AD: adenocarcinoma; AIP: autoimmune pancreatitis; BAC: broncholveolar carcinoma; DPAM: Disseminated peritoneal adenomucosis; CC: cholangiocarcinoma; CP: chronic pancreatitis; EUS: endoscopic ultrasound; FNA: fine needle aspirate; HCC: hepatocellular carcinoma; IACC: intraarterial cytoreductive chemotherapy

Table 1b Characteristics of patients with lung tumors in the included studies

Author Year [PMID] | N | Description | Histology and stage | Age | Treatments
Sasatomi 2002 [11980668] | 48 | Paraffin blocks from pts with NSCLC^g^; g non-small cell lung carcinoma; (1994–98); ≥2 y followup | Stage II NSCLC | Mean age: 66.4 y; 34/48 (71%) ≥ age 65 | Not stated
Sasatomi 2004 [15371943] | 34 | 14 cases of BAC & 20 cases of stage I AD | nonmucinous or mucinous BAC; G1–3 AD | BAC: mean age: 64 y; 7/14 (50%) ≥ age 65 Stage I AD: mean age: 67; 10/20 (50%) ≥ age 65 | Surgery
Dacic 2005 [15958854] | 20 | Paraffin blocks from pts with adenocarcinoma of the lung | Invasive (pathologic stage T4) | mean age: 70 y; 13/20 (65%) ≥ age 65 | Surgery [excluded those with preoperative chemotherapy or irradiation]
Fernando 2004 [14752417] | 40 | stage II NSCLC with standard pulmonary resection; adenocarcinoma or squamous carcinoma only; excluded pts with wedge or segmental resection; excluded T3N0 tumors | stage II NSCLC with affected N1 lymph nodes | median age: 68; range 42–85 | Lobectomy or pneumonectomy

ACC: acinar cell carcinoma; AD: adenocarcinoma; AIP: autoimmune pancreatitis; BAC: broncholveolar carcinoma; DPAM: Disseminated peritoneal adenomucosis; CC: cholangiocarcinoma; CP: chronic pancreatitis; EUS: endoscopic ultrasound; FNA: fine needle aspirate; HCC: hepatocellular carcinoma; IACC: intraarterial cytoreductive chemotherapy

Table 1c Characteristics of patients with other tumors in the included studies

Author Year [PMID] | N | Description | Histology and stage | Age | Treatments
Sheikh 2004 [14707871] | 11 | Archival cases with paraffin blocks available | Medullary thyroid carcinoma (sporadic); Stage II, III, IV | Mean age 48 [range: 17–72]; 5/11 men | Not stated
Maheshwari 2006 [17009159] | 23 | Archival cases with paraffin blocks available | Pseudomyxoma peritonei; DPAM (benign), PMCA (aggressive), intermediate | Mean age 54 [range: 27–90]; 17/23 men | Debulking surgery +/− intraperitoneal chemotherapy (n=22)
Tse 2006 [16386976]^h^; h Described as retrospective case series, comparative. | 16 | Archival cases with paraffin blocks available | Lacrimal gland adenoid cystic carcinoma | Not stated | Chemotherapy (IACC) and orbital exenteration and chemoradiotherapy (n=9) Conventional therapies (n=7)^i^; i Only 7 of 16 patients treated with conventional therapy between 1967 and 1994 had available tissue blocks for this study
Finkelstein 2004 [15151207] | 16^j^; j 85 samples in total. Molecular profiling was applied prospectively to 16 diagnostically challenging cases of reactive gliosis versus glioma; the study included retrospective analysis of 15 cases of clear reactive gliosis and 54 cases of various gliomas to check molecular profiles in these 2 entities, and then applied molecular analyses in the 16 challenging cases. | Prospective cases with challenging diagnosis between reactive gliosis and glioma | [Patients in whom pathologic diagnosis between reactive gliosis and glioma was difficult] | Not stated | Not stated

ACC: acinar cell carcinoma; AD: adenocarcinoma; AIP: autoimmune pancreatitis; BAC: broncholveolar carcinoma; DPAM: Disseminated peritoneal adenomucosis; CC: cholangiocarcinoma; CP: chronic pancreatitis; EUS: endoscopic ultrasound; FNA: fine needle aspirate; HCC: hepatocellular carcinoma; IACC: intraarterial cytoreductive chemotherapy

### Topographic genotyping

Manual microdissection was used in all studies. The examined genetic markers were microsatellites near genes implicated in carcinogenesis. Table 2a, 2b, and 2c list the examined microsatellites and genes in their proximity.

LOH was defined similarly in all studies. Typically, the operational definition of positive LOH was that the corresponding allelic peaks from tumor and normal tissue areas differed at least two-fold. FAL was the aggregate score in all studies. FAL is the proportion of informative microsatellites that have LOH. Some studies also examined mutations in K-ras (no details on which mutations). The presence of such mutations was taken into account together with the LOH markers in the construction of the aggregate score (which was termed “fractional mutation rate”).

No studies examined other ways to utilize the genetic information (e.g., using all markers in a multivariate model as individual predictors, or constructing a different score). However, FAL is a simple aggregate score, and the studies were of limited sample size to allow for meaningful exploration of alternative analyses.

FAL cutoffs to classify tumors differed across studies (e.g., FAL>0 or above and below the median) and appeared to be selected post-hoc. None was validated in an independent sample. A single study21 reported using a FAL cutoff determined in previous analyses.19 However, it is likely that patients included in these studies overlap extensively.

Only three studies clearly reported any validation of the reliability of LOH analyses (concordance between different readers or in repeat testing). Four publications clearly stated that the pathologist was blinded to clinical information1,20,23,25 (two1,23 likely referred to the same patients).

Table 2a Characteristics of genetic analyses in studies of gastrointestinal cancers

Author Year [PMID] | Marker panel | Nearby genes | Definitions of marker positivity | Aggregate score; cutoff | Validation or reliability | Blinding of assessor
Cong 2001 [11260864] | Not stated | APC DCC OGG1 p53 | - Positive LOH: >80% reduction of radiographic signal intensity of a polymorphic allele compared with normal | - FAL | Not stated | Not stated
Finkelstein 2003 [12668980] | D1S407 MYCL D3S1539 D3S2303 D5S592 D5S615 MCC DS71530 D8S373 D9S251 D9S254 D10S520 D10S1173 TP53 D17S974 D17S1289 D17S1163 D18S814 | Not stated | - Positive LOH: The ratio of allelic peak heights > 2.00 or < 0.50 | - FAL | Not stated | Blinded to clinical and pathological data
Marsh 2003 [12827550] | D1S407 MYCL D3S1539 D3S2303 D5S592 D5S615 MCC DS71530 D8S373 D9S251 D9S254 D10S520 D10S1173 TP53 D17S974 D17S1289 D17S1163 D18S814 | See footnote ^k^ | - Positive LOH: The ratio of allelic peak heights > 2.00 or < 0.50 | - FAL | Validation was performed in 22 patients (concordance > 50%) | Blinded to clinical (?and pathological) data
Khalid 2004 [15542529] | D1S407 MYCL | CMM/RIZ | - Positive LOH: The ratio of allelic peak heights > 2.00 or < 0.50 | - FAL (modified to include K-ras mutations) | Not stated | Not stated
Khalid 2004 [15542529] | D3S1539 D3S2303 | VHL | - Positive LOH: The ratio of allelic peak heights > 2.00 or < 0.50 | - FAL (modified to include K-ras mutations) | Not stated | Not stated
Khalid 2004 [15542529] | D5S592 D5S615 | APC | - Positive LOH: The ratio of allelic peak heights > 2.00 or < 0.50 | - FAL (modified to include K-ras mutations) | Not stated | Not stated
Khalid 2004 [15542529] | D9S251 D9S254 | CDKN2A/p16 | - Positive LOH: The ratio of allelic peak heights > 2.00 or < 0.50 | - FAL (modified to include K-ras mutations) | Not stated | Not stated
Khalid 2004 [15542529] | D10S520 D10S1173 | PTEN | - Positive LOH: The ratio of allelic peak heights > 2.00 or < 0.50 | - FAL (modified to include K-ras mutations) | Not stated | Not stated
Khalid 2004 [15542529] | D17S974 D17S1289 | p53 | - Positive LOH: The ratio of allelic peak heights > 2.00 or < 0.50 | - FAL (modified to include K-ras mutations) | Not stated | Not stated
Khalid 2004 [15542529] | “Point mutations” | K-ras^*^ | - Positive LOH: The ratio of allelic peak heights > 2.00 or < 0.50 | - FAL (modified to include K-ras mutations) | Not stated | Not stated
Khalid 2006 [17029619] | D1S407 MYCL | CMM/RIZ | - LOH: The ratio of allelic peak heights falling outside of two standard deviations beyond the mean for allele pairing | - FAL (modified to include K-ras mutations) | Not stated | Blinded to patient identity and diagnosis
Khalid 2006 [17029619] | D3S1539 D3S2303 | VHL | - LOH: The ratio of allelic peak heights falling outside of two standard deviations beyond the mean for allele pairing | - FAL (modified to include K-ras mutations) | Not stated | Blinded to patient identity and diagnosis
Khalid 2006 [17029619] | D5S592 D5S615 | APC | - LOH: The ratio of allelic peak heights falling outside of two standard deviations beyond the mean for allele pairing | - FAL (modified to include K-ras mutations) | Not stated | Blinded to patient identity and diagnosis
Khalid 2006 [17029619] | D9S251 D9S254 | p16 | - LOH: The ratio of allelic peak heights falling outside of two standard deviations beyond the mean for allele pairing | - FAL (modified to include K-ras mutations) | Not stated | Blinded to patient identity and diagnosis
Khalid 2006 [17029619] | D9S252 | PTCH | - LOH: The ratio of allelic peak heights falling outside of two standard deviations beyond the mean for allele pairing | - FAL (modified to include K-ras mutations) | Not stated | Blinded to patient identity and diagnosis
Khalid 2006 [17029619] | D10S520 D10S1173 | PTEN | - LOH: The ratio of allelic peak heights falling outside of two standard deviations beyond the mean for allele pairing | - FAL (modified to include K-ras mutations) | Not stated | Blinded to patient identity and diagnosis
Khalid 2006 [17029619] | D17S974 D17S1289 | p53 | - LOH: The ratio of allelic peak heights falling outside of two standard deviations beyond the mean for allele pairing | - FAL (modified to include K-ras mutations) | Not stated | Blinded to patient identity and diagnosis
Khalid 2006 [17029619] | D17S1161 | Her2/neu | - LOH: The ratio of allelic peak heights falling outside of two standard deviations beyond the mean for allele pairing | - FAL (modified to include K-ras mutations) | Not stated | Blinded to patient identity and diagnosis
Khalid 2006 [17029619] | D21S1244 | ETS2 | - LOH: The ratio of allelic peak heights falling outside of two standard deviations beyond the mean for allele pairing | - FAL (modified to include K-ras mutations) | Not stated | Blinded to patient identity and diagnosis
Khalid 2006 [17029619] | D22S532 | NF2 | - LOH: The ratio of allelic peak heights falling outside of two standard deviations beyond the mean for allele pairing | - FAL (modified to include K-ras mutations) | Not stated | Blinded to patient identity and diagnosis
Khalid 2006 [17029619] | “Point mutations” | K-ras | - LOH: The ratio of allelic peak heights falling outside of two standard deviations beyond the mean for allele pairing | - FAL (modified to include K-ras mutations) | Not stated | Blinded to patient identity and diagnosis
Schwartz 2008 [18602719] | MYCL 5NT | L-MYC | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | D1S407 | [NONE] | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | D3S2303 | OGG1 | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | D3S1539 | OGG1 | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | MCC E10 | MCC | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | D5S592 | APC | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | D5S615 | APC | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | D7S1530 | MET | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | D8S373 | C-MYC | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | D9S251 | CDKN2A | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | D9S254 | CDKN2A | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | D10S520 | PTEN | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | D10S1173 | PTEN | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | D17S1289 | TP53 | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | D17S974 | TP53 | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | TP53 L1 | TP53 | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | D17S1163 | [NONE] | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Schwartz 2008 [18602719] | D18S814 | DCC | - Positive LOH: When the ratio of the individual allele peaks fell outside the range of 0.66 to 1.50. | - FAL; - Cutoff was 0.27, based on the ROC curve that discriminates recurrence from non-recurrence in the studied population. | Replicate analysis performed in every case. Concordance of 85–100% and SD from 0.06 to 0.20. | Not stated
Fasanella 2009 [19152901] | [broad panel of markers located on chromosomal arms 1p, 3p, 5q, 9p, 10q, 11q, 17p, 17q, 21q and 22q] | [not stated] | - Positive LOH: When the ratio of the individual allele peaks fell outside 2 SDs beyond the mean. | - FAL; - Cutoff was 0.2, based on previous analyses (?)^l^ | Not stated | Not stated^m^

FAL: fractional allelic loss; SD: standard deviation

Table 2b Characteristics of genetic analyses in studies of lung cancers

Author Year [PMID] | Marker panel | Nearby genes | Definitions of marker positivity | Aggregate score; cutoff | Validation or reliability | Blinding of assessor
Sasatomi 2002 [11980668] | D1S407 | CMM | - Positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL; - If any had FAL (>0.0) | Concordance ratio of positive LOH between 2 independent observers was 100% | Not stated
Sasatomi 2002 [11980668] | MYCL1^n^ | MYCL1 | - Positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL; - If any had FAL (>0.0) | Concordance ratio of positive LOH between 2 independent observers was 100% | Not stated
Sasatomi 2002 [11980668] | D3S1539 | VHL | - Positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL; - If any had FAL (>0.0) | Concordance ratio of positive LOH between 2 independent observers was 100% | Not stated
Sasatomi 2002 [11980668] | D3S2303 | | - Positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL; - If any had FAL (>0.0) | Concordance ratio of positive LOH between 2 independent observers was 100% | Not stated
Sasatomi 2002 [11980668] | D5S592 | APC | - Positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL; - If any had FAL (>0.0) | Concordance ratio of positive LOH between 2 independent observers was 100% | Not stated
Sasatomi 2002 [11980668] | D5S615 | MCC | - Positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL; - If any had FAL (>0.0) | Concordance ratio of positive LOH between 2 independent observers was 100% | Not stated
Sasatomi 2002 [11980668] | MCC d | | - Positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL; - If any had FAL (>0.0) | Concordance ratio of positive LOH between 2 independent observers was 100% | Not stated
Sasatomi 2002 [11980668] | D7S1530 | MET | - Positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL; - If any had FAL (>0.0) | Concordance ratio of positive LOH between 2 independent observers was 100% | Not stated
Sasatomi 2002 [11980668] | D8S373 | MYC | - Positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL; - If any had FAL (>0.0) | Concordance ratio of positive LOH between 2 independent observers was 100% | Not stated
Sasatomi 2002 [11980668] | D9S254 | CDKN2A | - Positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL; - If any had FAL (>0.0) | Concordance ratio of positive LOH between 2 independent observers was 100% | Not stated
Sasatomi 2002 [11980668] | D9S251 | | - Positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL; - If any had FAL (>0.0) | Concordance ratio of positive LOH between 2 independent observers was 100% | Not stated
Sasatomi 2002 [11980668] | D10S520 | PTEN | - Positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL; - If any had FAL (>0.0) | Concordance ratio of positive LOH between 2 independent observers was 100% | Not stated
Sasatomi 2002 [11980668] | D10S1173 | MX11 | - Positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL; - If any had FAL (>0.0) | Concordance ratio of positive LOH between 2 independent observers was 100% | Not stated
Sasatomi 2002 [11980668] | D17S1163 | TP53 | - Positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL; - If any had FAL (>0.0) | Concordance ratio of positive LOH between 2 independent observers was 100% | Not stated
Sasatomi 2002 [11980668] | TP53 d | | - Positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL; - If any had FAL (>0.0) | Concordance ratio of positive LOH between 2 independent observers was 100% | Not stated
Sasatomi 2002 [11980668] | D18S814 | DCC | - Positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL; - If any had FAL (>0.0) | Concordance ratio of positive LOH between 2 independent observers was 100% | Not stated
Sasatomi 2004 [15371943] | D1S407 | CMM | - positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL | Not stated | Not stated
Sasatomi 2004 [15371943] | MYCL1^d^ | MYCL1 | - positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL | Not stated | Not stated
Sasatomi 2004 [15371943] | D3S1539 | VHL | - positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL | Not stated | Not stated
Sasatomi 2004 [15371943] | D3S2303 | | - positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL | Not stated | Not stated
Sasatomi 2004 [15371943] | D5S615 | APC | - positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL | Not stated | Not stated
Sasatomi 2004 [15371943] | MCC d | MCC | - positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL | Not stated | Not stated
Sasatomi 2004 [15371943] | D7S1530 | MET | - positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL | Not stated | Not stated
Sasatomi 2004 [15371943] | D8S373 | MYC | - positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL | Not stated | Not stated
Sasatomi 2004 [15371943] | D9S251 | CDKN2A | - positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL | Not stated | Not stated
Sasatomi 2004 [15371943] | D9S254 | | - positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL | Not stated | Not stated
Sasatomi 2004 [15371943] | D10S1173 | MX11 | - positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL | Not stated | Not stated
Sasatomi 2004 [15371943] | D10S520 | PTEN | - positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL | Not stated | Not stated
Sasatomi 2004 [15371943] | D17S974 | TP53 | - positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL | Not stated | Not stated
Sasatomi 2004 [15371943] | D17S1289 | | - positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL | Not stated | Not stated
Sasatomi 2004 [15371943] | D18S814 | DCC | - positive LOH: ratio between informative allelic band heights of <0.5 or >2.0; LOH of a chromosome region is positive if any of the microdissected sample showed LOH | - FAL | Not stated | Not stated
Dacic 2005 [15958854] | D1S407 | CMM | - positive LOH: ratio for the specific microsatellite marker was <0.6 or >1.5 | - FAL; - ≤0.40 vs. >0.40 | Not stated | Not stated
Dacic 2005 [15958854] | D1S1193 | | - positive LOH: ratio for the specific microsatellite marker was <0.6 or >1.5 | - FAL; - ≤0.40 vs. >0.40 | Not stated | Not stated
Dacic 2005 [15958854] | MYCL1 | MYCL1 | - positive LOH: ratio for the specific microsatellite marker was <0.6 or >1.5 | - FAL; - ≤0.40 vs. >0.40 | Not stated | Not stated
Dacic 2005 [15958854] | D3S1539 | VHL | - positive LOH: ratio for the specific microsatellite marker was <0.6 or >1.5 | - FAL; - ≤0.40 vs. >0.40 | Not stated | Not stated
Dacic 2005 [15958854] | D3S2303 | | - positive LOH: ratio for the specific microsatellite marker was <0.6 or >1.5 | - FAL; - ≤0.40 vs. >0.40 | Not stated | Not stated
Dacic 2005 [15958854] | D5S592 | APC | - positive LOH: ratio for the specific microsatellite marker was <0.6 or >1.5 | - FAL; - ≤0.40 vs. >0.40 | Not stated | Not stated
Dacic 2005 [15958854] | D5S615 | | - positive LOH: ratio for the specific microsatellite marker was <0.6 or >1.5 | - FAL; - ≤0.40 vs. >0.40 | Not stated | Not stated
Dacic 2005 [15958854] | D9S251 | CDKN2A | - positive LOH: ratio for the specific microsatellite marker was <0.6 or >1.5 | - FAL; - ≤0.40 vs. >0.40 | Not stated | Not stated
Dacic 2005 [15958854] | D9S254 | | - positive LOH: ratio for the specific microsatellite marker was <0.6 or >1.5 | - FAL; - ≤0.40 vs. >0.40 | Not stated | Not stated
Dacic 2005 [15958854] | D9S252 | not applicable | - positive LOH: ratio for the specific microsatellite marker was <0.6 or >1.5 | - FAL; - ≤0.40 vs. >0.40 | Not stated | Not stated
Dacic 2005 [15958854] | D10S1173 | MX11 | - positive LOH: ratio for the specific microsatellite marker was <0.6 or >1.5 | - FAL; - ≤0.40 vs. >0.40 | Not stated | Not stated
Dacic 2005 [15958854] | D10S520 | PTEN | - positive LOH: ratio for the specific microsatellite marker was <0.6 or >1.5 | - FAL; - ≤0.40 vs. >0.40 | Not stated | Not stated
Dacic 2005 [15958854] | D17S974 | TP53 | - positive LOH: ratio for the specific microsatellite marker was <0.6 or >1.5 | - FAL; - ≤0.40 vs. >0.40 | Not stated | Not stated
Dacic 2005 [15958854] | D17S1289 | | - positive LOH: ratio for the specific microsatellite marker was <0.6 or >1.5 | - FAL; - ≤0.40 vs. >0.40 | Not stated | Not stated
Dacic 2005 [15958854] | D22S532 | | - positive LOH: ratio for the specific microsatellite marker was <0.6 or >1.5 | - FAL; - ≤0.40 vs. >0.40 | Not stated | Not stated
Fernando 2004 [14752417] | D1S407 | L-myc | - LOH: diminished band activity ≥50% of the other corresponding bands for chromosome loci that were informative | - FAL | Not stated | Not stated
Fernando 2004 [14752417] | MYCL1 | | - LOH: diminished band activity ≥50% of the other corresponding bands for chromosome loci that were informative | - FAL | Not stated | Not stated
Fernando 2004 [14752417] | D3S1539 | OGG1 | - LOH: diminished band activity ≥50% of the other corresponding bands for chromosome loci that were informative | - FAL | Not stated | Not stated
Fernando 2004 [14752417] | D3S2303 | | - LOH: diminished band activity ≥50% of the other corresponding bands for chromosome loci that were informative | - FAL | Not stated | Not stated
Fernando 2004 [14752417] | D5S592 | APC | - LOH: diminished band activity ≥50% of the other corresponding bands for chromosome loci that were informative | - FAL | Not stated | Not stated
Fernando 2004 [14752417] | D5S615 | | - LOH: diminished band activity ≥50% of the other corresponding bands for chromosome loci that were informative | - FAL | Not stated | Not stated
Fernando 2004 [14752417] | MCC.E10 | | - LOH: diminished band activity ≥50% of the other corresponding bands for chromosome loci that were informative | - FAL | Not stated | Not stated
Fernando 2004 [14752417] | D7S1530 | c-MET | - LOH: diminished band activity ≥50% of the other corresponding bands for chromosome loci that were informative | - FAL | Not stated | Not stated

Table 2c Characteristics of genetic analyses in studies of other tumors

Author Year [PMID] | Marker panel | Nearby genes | Definitions of marker positivity | Aggregate score; cutoff | Validation or reliability | Blinding of assessor
Sheikh 2004 [14707871] | MYCL.5NT | L-MYC | - Ratio of allele peaks <0.6 or >1.6 | - FAL; - 1 point for each of FAL>0.50; age>50; positive LN | Not stated | Not stated
Sheikh 2004 [14707871] | D1S407 | CMM | - Ratio of allele peaks <0.6 or >1.6 | - FAL; - 1 point for each of FAL>0.50; age>50; positive LN | Not stated | Not stated
Sheikh 2004 [14707871] | D3S1539 | VHL | - Ratio of allele peaks <0.6 or >1.6 | - FAL; - 1 point for each of FAL>0.50; age>50; positive LN | Not stated | Not stated
Sheikh 2004 [14707871] | D5S615 | APC | - Ratio of allele peaks <0.6 or >1.6 | - FAL; - 1 point for each of FAL>0.50; age>50; positive LN | Not stated | Not stated
Sheikh 2004 [14707871] | D5S592 | MCC | - Ratio of allele peaks <0.6 or >1.6 | - FAL; - 1 point for each of FAL>0.50; age>50; positive LN | Not stated | Not stated
Sheikh 2004 [14707871] | D9S252 | PTCH1 | - Ratio of allele peaks <0.6 or >1.6 | - FAL; - 1 point for each of FAL>0.50; age>50; positive LN | Not stated | Not stated
Sheikh 2004 [14707871] | D9S254 | MTS1/p16 | - Ratio of allele peaks <0.6 or >1.6 | - FAL; - 1 point for each of FAL>0.50; age>50; positive LN | Not stated | Not stated
Sheikh 2004 [14707871] | D9S251 | MTS1/p16 | - Ratio of allele peaks <0.6 or >1.6 | - FAL; - 1 point for each of FAL>0.50; age>50; positive LN | Not stated | Not stated
Sheikh 2004 [14707871] | D17S974 | p53 | - Ratio of allele peaks <0.6 or >1.6 | - FAL; - 1 point for each of FAL>0.50; age>50; positive LN | Not stated | Not stated
Sheikh 2004 [14707871] | D17S1289 | p53 | - Ratio of allele peaks <0.6 or >1.6 | - FAL; - 1 point for each of FAL>0.50; age>50; positive LN | Not stated | Not stated
Sheikh 2004 [14707871] | D22S417 | NF2 | - Ratio of allele peaks <0.6 or >1.6 | - FAL; - 1 point for each of FAL>0.50; age>50; positive LN | Not stated | Not stated
Maheshwari 2006 [17009159] | D3S2303 or D3S1539^o^ | VHL | - Ratio of allele peaks <0.5 or >2, or beyond 2 SDs of the marker mean;; - Unclear for K-ras-2 point mutations | - FAL <25%, 25–50%, and >50% | Not stated | Not stated
Maheshwari 2006 [17009159] | D5S592 or D5S615^a^; a It is possible to use an ordinary microscope also. However, the image in the ordinary microscope is inverted and for some magnifications the distance between the microscope lens and the glass slide is too small to allow for easy microdissection.3 | MCC or APC | - Ratio of allele peaks <0.5 or >2, or beyond 2 SDs of the marker mean;; - Unclear for K-ras-2 point mutations | - FAL <25%, 25–50%, and >50% | Not stated | Not stated
Maheshwari 2006 [17009159] | D7S1530 | | - Ratio of allele peaks <0.5 or >2, or beyond 2 SDs of the marker mean;; - Unclear for K-ras-2 point mutations | - FAL <25%, 25–50%, and >50% | Not stated | Not stated
Maheshwari 2006 [17009159] | D9S252 | PTCH1 | - Ratio of allele peaks <0.5 or >2, or beyond 2 SDs of the marker mean;; - Unclear for K-ras-2 point mutations | - FAL <25%, 25–50%, and >50% | Not stated | Not stated
Maheshwari 2006 [17009159] | D17S974 | p53 | - Ratio of allele peaks <0.5 or >2, or beyond 2 SDs of the marker mean;; - Unclear for K-ras-2 point mutations | - FAL <25%, 25–50%, and >50% | Not stated | Not stated
Maheshwari 2006 [17009159] | D17S1289 | p53 | - Ratio of allele peaks <0.5 or >2, or beyond 2 SDs of the marker mean;; - Unclear for K-ras-2 point mutations | - FAL <25%, 25–50%, and >50% | Not stated | Not stated
Maheshwari 2006 [17009159] | “point mutations” ^p^ | K-ras-2 | - Ratio of allele peaks <0.5 or >2, or beyond 2 SDs of the marker mean;; - Unclear for K-ras-2 point mutations | - FAL <25%, 25–50%, and >50% | Not stated | Not stated
Tse 2006 [16386976] | D1S407 | CMM | - Ratio of allele peaks beyond 2 SDs of the marker mean | - FAL | Not stated | Blinded to clinical data
Tse 2006 [16386976] | D3S1539 | VHL | - Ratio of allele peaks beyond 2 SDs of the marker mean | - FAL | Not stated | Blinded to clinical data
Tse 2006 [16386976] | D3S2303 | OGG1 | - Ratio of allele peaks beyond 2 SDs of the marker mean | - FAL | Not stated | Blinded to clinical data
Tse 2006 [16386976] | D5S615 | APC | - Ratio of allele peaks beyond 2 SDs of the marker mean | - FAL | Not stated | Blinded to clinical data
Tse 2006 [16386976] | D5S592 | MCC | - Ratio of allele peaks beyond 2 SDs of the marker mean | - FAL | Not stated | Blinded to clinical data
Tse 2006 [16386976] | D9S252 | PTCH1 | - Ratio of allele peaks beyond 2 SDs of the marker mean | - FAL | Not stated | Blinded to clinical data
Tse 2006 [16386976] | D9S254 | MTS1/p16 | - Ratio of allele peaks beyond 2 SDs of the marker mean | - FAL | Not stated | Blinded to clinical data
Tse 2006 [16386976] | D9S251 | MTS1/p16 | - Ratio of allele peaks beyond 2 SDs of the marker mean | - FAL | Not stated | Blinded to clinical data
Tse 2006 [16386976] | D10S520 | PTEN | - Ratio of allele peaks beyond 2 SDs of the marker mean | - FAL | Not stated | Blinded to clinical data
Tse 2006 [16386976] | D10S1173 | PTEN(?) | - Ratio of allele peaks beyond 2 SDs of the marker mean | - FAL | Not stated | Blinded to clinical data
Tse 2006 [16386976] | D17S974 | p53 | - Ratio of allele peaks beyond 2 SDs of the marker mean | - FAL | Not stated | Blinded to clinical data
Tse 2006 [16386976] | D17S1289 | p53 | - Ratio of allele peaks beyond 2 SDs of the marker mean | - FAL | Not stated | Blinded to clinical data
Tse 2006 [16386976] | D17S1161 | NME1(?) | - Ratio of allele peaks beyond 2 SDs of the marker mean | - FAL | Not stated | Blinded to clinical data
Tse 2006 [16386976] | D22S417 | NF2 | - Ratio of allele peaks beyond 2 SDs of the marker mean | - FAL | Not stated | Blinded to clinical data
Finkelstein 2004 [15151207] | MYCL D1S407 | L-myc | Not stated | - FAL | Not stated | Not stated
Finkelstein 2004 [15151207] | D1S1193 | | Not stated | - FAL | Not stated | Not stated
Finkelstein 2004 [15151207] | D3S2303 | | Not stated | - FAL | Not stated | Not stated
Finkelstein 2004 [15151207] | D3S1539 | OGG1 | Not stated | - FAL | Not stated | Not stated
Finkelstein 2004 [15151207] | D5S592 | APC | Not stated | - FAL | Not stated | Not stated
Finkelstein 2004 [15151207] | D5S615 | | Not stated | - FAL | Not stated | Not stated
Finkelstein 2004 [15151207] | D9S251 | | Not stated | - FAL | Not stated | Not stated
Finkelstein 2004 [15151207] | D9S254 | p16 | Not stated | - FAL | Not stated | Not stated
Finkelstein 2004 [15151207] | D10S520 | | Not stated | - FAL | Not stated | Not stated
Finkelstein 2004 [15151207] | D10S1173 | PTEN | Not stated | - FAL | Not stated | Not stated
Finkelstein 2004 [15151207] | D17S974 | TP53 | Not stated | - FAL | Not stated | Not stated
Finkelstein 2004 [15151207] | D17S1289 | | Not stated | - FAL | Not stated | Not stated
Finkelstein 2004 [15151207] | D19S559 | | Not stated | - FAL | Not stated | Not stated

### Results

Table 3a, 3b and 3c summarize study findings.

#### Diagnostic accuracy (Level 2)

Two studies,19,20 evaluated the diagnostic ability of loss-of-heterozygosity based topographic genotyping with PathfinderTG® to identified malignancy in Papanicolaou-stained smears from pancreaticobiliary cytology. Pathological confirmation of surgical specimens or long-term clinical followup was used as the reference standard.

In both studies, all samples with positive cytology had FAL>0. All samples with negative cytology had FAL=0 (with one exception in one study20). Using the above cutoffs, loss-of-heterozygosity based topographic genotyping with PathfinderTG® correctly classified all cases (10^19^ and 11^20^) that were inconclusive with cytology analyses.

One study applied prospectively loss-of-heterozygosity based topographic genotyping with PathfinderTG® to distinguish reactive gliosis from glioma in 16 diagnostically challenging cases.2 Sensitivity was 89% (8/9) and specificity 100% (7/7). However, these estimates are extremely uncertain (small sample): the confidence intervals range from approximately 50% to 100% for both sensitivity and specificity.

#### Prognostic accuracy (Level 2)

The remaining 12 publications evaluated the association of PathfinderTG® aggregate scores and survival, recurrence-free survival, and tumor recurrence. Retrospectively collected clinical data were used to ascertain outcomes.

Treatment was not used as a covariate in all but one study.22 This was the only eligible study that presented multivariate analysis estimates. One additional study21 specifically commented that multivariate analyses were not possible because of complete separation of the outcome categories by the predictor (FAL equal to or greater than 0.20). In all other studies, confounders of the relationship between FAL and clinical outcome were not reported or adjusted for.

Cutoff selection (for FAL) appears to have been selected post-hoc (cutoffs across studies ranged from 0 to 0.63, when reported). In nine publications FAL was identified as a statistically significant predictor of a clinical outcome in at least one analysis or subgroup and for the presented cutoffs.

In three studies there were no statistically significant associations between FAL and the examined clinical outcomes in any analysis or subgroup.14,17,25

#### Impact on diagnostic thinking (Level 3)

Here we are interested in whether using loss-of-heterozygosity based topographic genotyping with PathfinderTG® affects the ordering of additional diagnostic tests. No study provided relevant data. However, as mentioned above under “Diagnostic accuracy”, loss-of-heterozygosity based topographic genotyping with PathfinderTG® correctly classified 10 and 11 cases that were “inconclusive” with simple cytology alone in two studies.

#### Impact on treatment decisions (Level 4)

Here we are interested in changes in treatment decisions given the results of loss-of-heterozygosity based topographic genotyping with PathfinderTG® compared to treatment decisions in the absence of such information. No study provided relevant data.

#### Impact on patient outcomes (Level 5)

No studies evaluated whether the use of loss-of-heterozygosity based topographic genotyping with PathfinderTG® affects patient outcomes.

Table 3a Study findings for gastrointestinal tumors

Author Year [PMID] | Aggregate score cutoff | Outcome definition | Statistical analysis and results
Cong 2001 [11260864] | Not stated | Survival after surgery by groups based-on specific LOH loci | 3-y survival by Group [KM] I: 0%, II: 89%, III: 30% (P=0.049 [II vs. III])
Finkelstein 2003 [12668980] | 0.3 (median of the whole samples) | Recurrence-free survival (RFS) after hepatic transplant | 5-y RFS by allelic loss [KM]; - FAL > 0.3: 12% vs. 97% (P<0.0001); - Reclassified T-stage based on allelic loss (T4 vs. T3 vs. T2/1): 0% vs. 42% vs. 85% (P<0.02); Multivariate analysis Vascular invasion (P=0.001), largest tumor size (P=0.003), and FAL (P=0.001) were statistically significant independent risk factors to predict recurrence (Cox model, backward stepwise elimination)
Marsh 2003 [12827550] | Not stated | Recurrence-free survival (RFS) after hepatic transplant | Univariate survival analysis; - 9/18 markers were statistically significant (P<0.05) by log-rank test; Prognostic accuracy of FAL; - 5/103 (5%) excluded; - 44/103 (43%) inconclusive test; - Sensitivity of 94% (17/18); - Specificity of 97% (35/36); Prognostic accuracy of ANN of common prognostic factors and FAL; - 10/103 (10%) excluded; - 12/103 (12%) inconclusive test; - Sensitivity 100% (29/29); - Specificity 100% (52/52)
Khalid 2004 [15542529] | Not stated | Diagnosis of cancer (inferred) | Mean FMR; - 0.45 for positive cytology vs. 0.38 for inconclusive cytology (NS); Diagnostic accuracy; - Sensitivity of 100% (17/17); - Specificity of 100% (9/9); - Accuracy of 100% (26/26); Diagnostic impact; - No changes in positive cytology; - No changes in negative cytology; 10 changes in inconclusive cytology (9 became [true] positive and 1 became [true] negative)
Khalid 2006 [17029619] | Not stated | Diagnosis of cancer (inferred) | Mean FAL; - 0.52 for positive cytology vs. 0.47 for inconclusive cytology (NS); Diagnostic accuracy; - Sensitivity of 100% (15/15); - Specificity of 83% (5/6); - Accuracy of 95% (20/21); Diagnostic impact; - No changes in positive cytology; Eleven changes in inconclusive cytology (5 became [true] positive, 1 became [false] positive, and 5 became [true] negative)
Schwartz 2008 [18602719] | 0.27 | Recurrence | Among all 70 patients, the cutoff of 0.27 in FAL (selected with an ROC for recurrence in the 70 patients) is a strong predictor of recurrence:; - HR 39.7 (95% CI: 5.3, 299.5) adjusted for Milan criteria, AFP, and histology (grade, invasiveness status); - [sensitivity and specificity not reported]; Among 35 patients beyond Milan criteria, FAL >=0.27 has; - Sensitivity 83%; - Specificity 91%; Among 35 patients beyond Milan criteria, a model including FAL and macroscopic vascular invasion (unclear if it includes other adjustments):; - Sensitivity 83%; - Specificity 91%
Fasanella 2009 [19152901] | 0.20 | Mortality Recurrence (based on CT) Progression (based on CT) | Median follow up was 30 mo (range 2, 66 months) From survival analyses, using the 0.20 cutoff for FAL (ten patients had FAL≥0.20):; - Survival: All eight deaths among those with FAL ≥0.20. Log rank p<0.001; - Progression or recurrence: All 10 events among those with FAL ≥0.20 (log rank p<0.0001).

AFP: alpha fetoprotein; CI: confidence interval; CT: computed tomography; FAL: fractional allelic loss; HR: hazard ratio; NS: not significant

Table 3b Study findings for lung tumors

Author Year [PMID] | Aggregate score cutoff | Outcome definition | Statistical analysis and results
Sasatomi 2002 [11980668] | 0.63 | Survival | P=0.552 median survival 3.3 y vs. 3.4 y (est.)
Sasatomi 2002 [11980668] | 0.50 | Survival | P=0.012 median survival 3 y vs. >7 y (est.)
Sasatomi 2004 [15371943] | 0.50 | Survival | In bronchoalveolar carcinoma: favoring low FAL group, P=0.098
Sasatomi 2004 [15371943] | 0.50 | Survival | In stage I adenocarcinoma: no correlation between LOH, maximum FAL and clinical outcome
Dacic 2005 [15958854] | 0.4 | Survival | P=0.159 median survival 59 mo vs. 10 mo
Fernando 2004 [14752417] | high risk (FAL_node_/FAL_tumor_ ratio ≥1); low risk (ratio <1) | Survival | squamous carcinoma: median survival 38 mo (est.) vs. 34 mo (est.); NS adenocarcinoma: median survival 25 mo vs. no death; P=0.01

AFP: alpha fetoprotein; CI: confidence interval; CT: computed tomography; FAL: fractional allelic loss; HR: hazard ratio; NS: not significant

Table 3c Study findings for other tumors

Author Year [PMID] | Aggregate score cutoff | Outcome definition | Statistical analysis and results
Sheikh 2004 [14707871] | Not applicable | Tumor recurrence | P=0.08 Mean FAL: Recurrent (n=6): 52% Non-recurrent (n=5): 34%
Sheikh 2004 [14707871] | FAL>0.50 | Tumor recurrence | P=0.10 High FAL: Recurrent: 4/6 Non-recurrent: 1/5
Sheikh 2004 [14707871] | >1 points | Tumor recurrence | P=0.004 2 or 3 points: Recurrent: 6/6 Non-recurrent: 0/5
Maheshwari 2006 [17009159] | FAL <25%, 25–50%, and >50% | Survival analysis | P<0.05 Worse FAL category is associated with worse survival
Tse 2006 [16386976] | Not stated | Survival [among 7 receiving conventional treatment] | P=0.15 No significant effect of FAL on time to death (direction of effects not reported)
Tse 2006 [16386976] | Not stated | Survival [all patients (stratified per therapy)] | P=Not stated No significant effect of FAL on time to death
Tse 2006 [16386976] | Not stated | Time to recurrence | P=0.15 (from 95% CI) HR 2.6 (95% CI: 0.7–9.3) per 20% increase in FAL
Finkelstein 2004 [15151207] | FAL>0 | Diagnosis of reactive gliosis vs glioma | Sensitivity: 8/9, 89% (95% CI 52, 100%) Specificity: 7/7, 100% (95% CI 59, 100%)

AFP: alpha fetoprotein; CI: confidence interval; CT: computed tomography; FAL : fractional allelic loss; HR: hazard ratio; NS: not significant

### Overview

All studies were retrospective in design and used archival tissue blocks that were available. In a single study, molecular profiles of gliomas and reactive gliosis were determined retrospectively, and then they were used prospectively on 16 diagnostically challenging cases of reactive gliosis versus glial tumors.2

Three publications examined the ability of loss-of-heterozygosity based topographic genotyping with PathfinderTG® to diagnose malignancy from pancreatico-biliary cytology specimens,19–21 whereas all other studies used tissue slides from solid tumors.

Microdissection and molecular analysis protocols were described in detail in all studies. However, details on patient (sample) selection, patient characteristics, treatments received, clinical endpoint definitions, justification of sample size, selection of cutoffs (for aggregate scores such as FAL), selection among various statistical models, and other important parameters of study design and reporting were provided inconsistently. Table 4 shows whether the assessed studies reported information suggested by the REMARK guidelines.

Table 4 Reporting of several characteristics across the eligible studies (items adopted from the REMARK statement)

| 18 | 1 | 23 | 19 | 20 | 16 | 22 | 21 | 17 | 14 | 15 | 24 | 26 | 25 | 2
Clearly stated study objectives | Y | N | Y | Y | N | Y | Y | Y | Y | Y | Y | Y | N^17^ | N | N
Described patient characteristics | Y | N | N | N | Y | Y | Y | Y | Y | Y | Y | Y | Y | N | N
Described treatments | N | N | N | NA | NA | N | N | Y | N | N | Y | N | N | N^18^ | N
Described biological materials | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y
Specified assay method | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y
Described method of case selection | Y | Y | Y | Y | Y | Y | Y | Y | N | N | Y | Y | Y | Y | N
Defined clinical endpoints | N | N | N | N | N | Y | N | N | Y | Y | Y | Y | Y | N^19^ | N
Listed all variables in model a priori | N | N | N | NA | NA | N | Y | N | Y | Y | Y | N | N | N | N
Explained sample size choice | N | N | N | N | N | N | N | N | N | N | N | N | N | N | N
Described statistical methods | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | N | N^20^ | N
Described methods for cutpoint determination | N | N | N | N | N | N | Y | N | N | N | Y | N | N | N | N
Described patient flow | N | N | N | N | N | N | Y | Y | N | N | N | N | N | N | N
Described demographics | Y | N | N | N | Y | Y | Y | Y | Y | Y | Y | N | N | N | N
Described relation of marker to standard predictors | N | Y^21^ | Y^22^ | NA | NA | Y | N | N | N | N | N | N | N | N | N
Presented univariable analyses | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | N | Y | Y
Reported multivariate analysis estimates | N | N | N | N | N | N | Y | NA^23^ | N | N | N | N | N | N | N
Provided estimates and confidence interval for all predictors | N | N | N | N | N | N | N | N | N | N | N | N | N | N | N
Any internal validation | N | Y | Y | N | N | Y | N | N | N | N | N | N | N | N | N
Described limitations of predictive instrument | N | N | N | N | Y | N | N | N | N | Y | N | N | N | N | N
Described implications for future research | N | N | N | N | N | Y | Y | Y | Y | N | Y | N | N | N | N

N: No/Not stated; NA: not applicable; Y: Yes

Studies ordered as in Table 1a, 1b, and 1c

## Key Question 3 Is there direct evidence comparing loss-of-heterozygosity based topographic genotyping with PathfinderTG® with conventional pathology without such analyses for clinical outcomes?

We did not identify eligible studies for this question.

## Key Question 4 Was informed consent and IRB approval obtained, and were institutional guidelines followed?

All studies except for two specifically mentioned that IRB approval was obtained for the specific study. Two studies18,24 did not mention any information. However, during the peer-review period the company clarified that all studies were conducted according to institutional mandates.

We clarify that for retrospective studies using archival samples and retrospective chart review it is generally not mandated to obtain informed consent from patients. Typically, the IRB would provide approval as long as the protocol of the study is in agreement with the international and institutional ethical mandates.

## Key Question 5 Applicability of studies to the Medicare population

None of the studies explicitly stated their applicability to the Medicare beneficiary population. Five studies did not provide any information on the age distribution of the included patients whose tumors were examined.1,2,19,23,25 In the remaining eight studies, mean ages ranged from 48 to 70 years (above 60 years in six studies; Table 1a, 1b, and 1c).

The applicability of the findings to Medicare beneficiaries cannot be easily deduced for several eligible studies. This is further complicated by the relative dearth of information on the selection process of the samples that were included in the analyses.