# Discussion

Most studies on loss-of-heterozygosity based topographic genotyping with PathfinderTG® were excluded because they only described the molecular profile of different tumors, without assessing the ability of the method to help make diagnosis, prognosis or treatment guidance. No studies directly measured whether using loss-of-heterozygosity based topographic genotyping with PathfinderTG® improves patient-relevant clinical outcomes. Eligible studies on the diagnostic and prognostic ability of loss-of-heterozygosity based topographic genotyping with PathfinderTG® were small in sample sizes and had overt methodological limitations. Important characteristics of their designs were not clearly reported. Most studies clearly reported receiving IRB approval. Evaluating the applicability of studies to the Medicare beneficiary population was hindered by the lack of details on patient characteristics.

Loss-of-heterozygosity based topographic genotyping with PathfinderTG® is claimed to be particularly useful in cases where conventional pathology is unable to provide a conclusive diagnosis. However, the included studies were not designed to address this question. (An exception is a single small study where loss-of-heterozygosity based topographic genotyping with PathfinderTG® was used prospectively in 16 patients with challenging differential diagnosis between reactive gliosis versus glioma.2) Therefore, it is unclear if the findings of the reviewed studies are directly applicable to patients with the same cancers but with inconclusive diagnosis.

Ultimately, the value of any diagnostic or prognostic test is determined by its ability to affect patient-relevant clinical outcomes. As of this writing, there are no studies –comparative or not– on whether patients who received loss-of-heterozygosity based topographic genotyping with PathfinderTG® testing had better survival, longer time to tumor recurrence, or fewer adverse outcomes attributable to unnecessary harmful interventions.

This systematic review identified several limitations of eligible studies on loss-of-heterozygosity based topographic genotyping with PathfinderTG®. First, all studies had very limited sample sizes and with one exception had performed only retrospective assessments. Although they provided details on pathologic and biochemical protocols, they did not provide important information on patient selection, patient characteristics, treatments received, clinical endpoint definitions, justification of sample size, selection of cutoffs (for aggregate scores such as FAL), and selection among various statistical models. There were strong indications that the selection of cutoffs in the aggregate score (FAL) was determined post-hoc: FAL cutoffs varied widely across studies (from 0 to 0.63) and were not validated in an external population (with a single exception of a prospective assessment of 16 cases). Finally, studies evaluating prognostic ability did not adjust for treatment or other predictors of outcome and did not provide multivariate analyses.

Allowing for the aforementioned caveats, it is theoretically and biologically plausible that topographic genotyping (including loss-of-heterozygosity based topographic genotyping with PathfinderTG®) may have prognostic and diagnostic ability, if one examines a suitable genetic marker panel for each type of cancer. The reviewed studies are suggestive of the above for the patented loss-of-heterozygosity based topographic genotyping with PathfinderTG® methodology. However, all studies are small, they have important methodological limitations, and they do not address patient-relevant outcomes.