# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Heather Brown, M.D.
  Senior Scientist
  Technology Evaluation Center
  Blue Cross Blue Shield Association
  Chicago, IL
- Michael R. Emmert-Buck, M.D., Ph.D.
  Head of Pathogenics Unit
  National Cancer Institute
  Gaithersburg, MD
- Steven Gutman, M.D.
  Professor of Pathology
  University of Central Florida
  Orlando, FL