# References

1 Finkelstein SD, Marsh W, Demetris AJ, Swalsky PA, Sasatomi E, Bonham A, et al. Microdissection-based allelotyping discriminates de novo tumor from intrahepatic spread in hepatocellular carcinoma. Hepatology. 2003;37:871-879. [pmid: 12668980].
2 Finkelstein SD, Mohan D, Hamilton RL, Sasatomi E, Swalsky PA, Lieberman FS. Microdissection-based genotyping assists discrimination of reactive gliosis from glioma. Am J Clin Pathol. 2004;121:671-678. [pmid: 15151207].
3 Hunt JL, Finkelstein SD. Microdissection techniques for molecular testing in surgical pathology. [Review] [30 refs]. Archives of Pathology & Laboratory Medicine. 2004;128:1372-1378. [pmid: 15578881].
4 Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Med Decis Making. 1991;11:88-94. [pmid: 1907710].
5 Redon R, Ishikawa S, Fitch KR, Feuk L, Perry GH, Andrews TD, et al. Global variation in copy number in the human genome.[see comment]. Nature. 2006;444:444-454. [pmid: 17122850].
6 Turbett GR, Barnett TC, Dillon EK, Sellner LN. Single-tube protocol for the extraction of DNA or RNA from paraffin-embedded tissues using a starch-based adhesive. Biotechniques. 1996;20:846-843. [pmid: 8723930].
7 Shirasaki F, Takata M, Hatta N, Takehara K. Loss of expression of the metastasis suppressor gene KiSS1 during melanoma progression and its association with LOH of chromosome 6q16.3-q23. Cancer Res. 2001;61:7422-7425. [pmid: 11606374].
8 Ionescu DN, Sasatomi E, Aldeeb D, Omalu BI, Finkelstein SD, Swalsky PA, et al. Pulmonary meningothelial-like nodules: a genotypic comparison with meningiomas. American Journal of Surgical Pathology. 2004;28:207-214. [pmid: 15043310].
9 Lasko D, Cavenee W, Nordenskjold M. Loss of constitutional heterozygosity in human cancer. Annu Rev Genet. 1991;25:281-314. [pmid: 1687498].
10 Alberts B, Johnson A, Lewis J, Raff M, Roberts K, Walter P. Molecular biology of the cell. 5 ed. Garland Science. 2008.
11 Dreesen JC, Bras M, Coonen E, Dumoulin JC, Evers JL, Geraedts JP. Allelic dropout caused by allele-specific amplification failure in single-cell PCR of the cystic fibrosis delta F508 deletion. J Assist Reprod Genet. 1996;13:112-114. [pmid: 8688582].
12 Rechitsky S, Freidine M, Verlinsky Y, Strom CM. Allele dropout in sequential PCR and FISH analysis of single cells (cell recycling). J Assist Reprod Genet. 1996;13:115-124. [pmid: 8688583].
13 Finkelstein SD, Przygodzki R, Swalsky PA. Microdissection-Based p53 Genotyping: Concepts for Molecular Testing. Mol Diagn. 1998;3:179-191. [pmid: 10089578].
14 Dacic S, Ionescu DN, Finkelstein S, Yousem SA. Patterns of allelic loss of synchronous adenocarcinomas of the lung. Am J Surg Pathol. 2005;29:897-902. [pmid: 15958854].
15 Fernando HC, Sasatomi E, Christie NA, Buenaventura PO, Finkelstein SD, Yousem SA, et al. Comparison of mutational changes in involved N1 lymph nodes with those in primary tumors in stage II non-small cell lung cancer: a pilot study. Journal of Thoracic & Cardiovascular Surgery. 2004;127:87-91. [pmid: 14752417].
16 Sasatomi E, Finkelstein SD, Woods JD, Bakker A, Swalsky PA, Luketich JD, et al. Comparison of accumulated allele loss between primary tumor and lymph node metastasis in stage II non-small cell lung carcinoma: implications for the timing of lymph node metastasis and prognostic value. Cancer Research. 2002;62:2681-2689. [pmid: 11980668].
17 Sasatomi E, Johnson LR, Aldeeb DN, Lomago DM, Thompson JW Jr, Swalsky PA, et al. Genetic profile of cumulative mutational damage associated with early pulmonary adenocarcinoma: bronchioloalveolar carcinoma vs. stage I invasive adenocarcinoma. American Journal of Surgical Pathology. 2004;28:1280-1288. [pmid: 15371943].
18 Cong WM, Bakker A, Swalsky PA, Raja S, Woods J, Thomas S, et al. Multiple genetic alterations involved in the tumorigenesis of human cholangiocarcinoma: a molecular genetic and clinicopathological study. Journal of Cancer Research & Clinical Oncology. 2001;127:187-192. [pmid: 11260864].
19 Khalid A, Pal R, Sasatomi E, Swalsky P, Slivka A, Whitcomb D, et al. Use of microsatellite marker loss of heterozygosity in accurate diagnosis of pancreaticobiliary malignancy from brush cytology samples. Gut. 2004;53:1860-1865. [pmid: 15542529].
20 Khalid A, Nodit L, Zahid M, Bauer K, Brody D, Finkelstein SD, et al. Endoscopic ultrasound fine needle aspirate DNA analysis to differentiate malignant and benign pancreatic masses.[see comment]. American Journal of Gastroenterology. 2006;101:2493-2500. [pmid: 17029619].
21 Fasanella KE, McGrath KM, Sanders M, Brody D, Domsic R, Khalid A. Pancreatic endocrine tumor EUS-guided FNA DNA microsatellite loss and mortality. Gastrointest Endosc. 2009;69:1074-1080. [pmid: 19152901].
22 Schwartz M, Dvorchik I, Roayaie S, Fiel MI, Finkelstein S, Marsh JW, et al. Liver transplantation for hepatocellular carcinoma: extension of indications based on molecular markers. J Hepatol. 2008;49:581-588. [pmid: 18602719].
23 Marsh JW, Finkelstein SD, Demetris AJ, Swalsky PA, Sasatomi E, Bandos A, et al. Genotyping of hepatocellular carcinoma in liver transplant recipients adds predictive power for determining recurrence-free survival. Liver Transplantation. 2003;9:664-671. [pmid: 12827550].
24 Sheikh HA, Tometsko M, Niehouse L, Aldeeb D, Swalsky P, Finkelstein S, et al. Molecular genotyping of medullary thyroid carcinoma can predict tumor recurrence. Am J Surg Pathol. 2004;28:101-106. [pmid: 14707871].
25 Tse DT, Finkelstein SD, Benedetto P, Dubovy S, Schiffman J, Feuer WJ. Microdissection genotyping analysis of the effect of intraarterial cytoreductive chemotherapy in the treatment of lacrimal gland adenoid cystic carcinoma. Am J Ophthalmol. 2006;141:54-61. [pmid: 16386976].
26 Maheshwari V, Tsung A, Lin Y, Zeh HJ III, Finkelstein SD, Bartlett DL. Analysis of loss of heterozygosity for tumor-suppressor genes can accurately classify and predict the clinical behavior of mucinous tumors arising from the appendix. Annals of Surgical Oncology. 2006;13:1610-1616. [pmid: 17009159].
27 Shen J, Brugge WR, Dimaio CJ, Pitman MB. Molecular analysis of pancreatic cyst fluid: a comparative analysis with current practice of diagnosis. Cancer Cytopathol. 2009;117:217-227.