# Results

## Research Needs

### Prioritization Results

We conducted two rounds of prioritization to ultimately identify eight high-priority research needs. In the first round, the stakeholders determined that 16 of the 29 evidence gaps were of higher priority than the rest of the evidence gaps (Appendix E). Ten of the 12 stakeholders (83 percent) responded to the request to complete the first online prioritization exercise. The number of stars allocated to each evidence gap ranged from 1 to 10. Based on the distribution of the stars allotted to each gap, the upper-tier evidence gaps were the 15 gaps that received 5 or more stars. On reviewing the upper- and lower-tier gaps, the stakeholders requested that one of the lower-tier gaps be added to the upper tier and carried forward to the second round. This additional gap was one of two gaps that received four stars (Appendix E).

Between the first and second round of prioritization, the project team applied an evidence gaps, populations, interventions, comparators, outcomes, timeframes, and settings (PICOTS) framework to the evidence gaps and transformed them into research needs presented in the form of questions. Appendix F shows the list of 16 research needs that the stakeholders prioritized in the second round. Results from the second round of prioritization (Figure 2) are based on responses from 9 out of 12 stakeholders (75 percent). The number of stars allotted to each research need ranged from zero to 11. Out of 16 high-priority evidence gaps, 8 were deemed by the stakeholders as the highest priority research needs, representing essentially the top quartile of the original 29.

Figure 2 Distribution of stars among 16 research needs

RN = research need

Note: The dashed line represents the cutoff point between the upper-tier and lower-tier research needs. All research needs with five or more stars represent the stakeholders’ highest priorities.

This figure is a bar graph showing the distribution of stars among the 16 research needs considered by the stakeholders in the second round of prioritization. Each research need was assigned a variable code RN1 through RN16. These variable codes appear along the horizontal axis of the graph. The vertical axis on the left shows numbers 0 through 12. The number of stars for each research need is as follows: RN1 = 7; RN2 = 1; RN3 = 2; RN4 = 5; RN6 = 9; RN7 = 10; RN8 = 4' RN9 = 0; RN10 = 4; RN11 = 3; RN12 = 5; RN13 = 7; RN 14 = 2; RN15 = 11; RN 16 = 8. A dashed line runs from left to right at the level of number 4 to represent the cut-off point between the upper tier and lower tier research needs. The needs that received more than 4 stars represent the upper tier of the stakeholders' prioritized research needs. These are RN1, RN4, RN6, RN7, RN12, RN13, RN15, RN16.

Table 2 shows the eight highest-ranking research needs as determined by the second round of prioritization. Each of these received five or more stars. The number of stakeholders providing stars for each of the highest-ranking needs confirmed that these are of high priority for multiple stakeholders. For each of the eight highest-ranking needs, at least three stakeholders offered one star and at least one of those gave the need two or more stars. In contrast, only one of the lower eight received more than one star from a single stakeholder, and that gap received only three stars in total from two stakeholders. Two of the highest-ranked research needs were focused on methods issues, and three on children younger than 6 years old. These prioritized research needs span across all three Key Questions of the attention deficit hyperactivity disorder (ADHD) review.

Table 2 Eight highest priority research needs

Research Need | # of Stars | # of Stakeholders Contributing at Least one Star
For people of all ages diagnosed with ADHD, what are the most accurate, brief standardized tools for diagnosis and outcome measurement that can be administered in generalizable practice settings and used on a repeated basis, integrated into clinical care? | 11 | 6
For children less than 6 years old with disruptive behavior disorder or ADHD, what is the comparative efficacy, effectiveness, and harmfulness of the available pharmacological treatments, singularly or in combination with other pharmacologic interventions? | 10 | 7
For children less than 6 years old with disruptive behavior disorder or ADHD, what is the comparative efficacy and effectiveness for patient outcomes of differing combinations of psychosocial and pharmacological treatments for those who either are initiating treatment with psychosocial therapies or who have not improved on their current therapy? Are there discrete patient-level predictors that favor a particular treatment strategy? | 9 | 6
For people of all ages diagnosed with ADHD (and especially adolescents and adults), what methods provide the most useful data collection, assessment of prevalence, case identification, and outcomes measurements for studies involving epidemiologic surveys and administrative databases? | 8 | 5
For children less than 6 years old with disruptive behavior disorder or ADHD, what is the comparative efficacy and effectiveness of specific psychosocial treatments alone compared with pharmacological treatments alone or in combination with psychosocial treatments for patient outcomes? | 7 | 5
For people age 6 years or older with ADHD, what are the comparative long-term outcomes for the available psychosocial and pharmacological treatments? | 7 | 4
Among children less than 6 years old with disruptive behavior disorder or ADHD, what is the relative/comparative efficacy of key components of psychosocial treatment programs? These might include the relative efficacy of specific parent training compared with treatment components targeting the child, or the efficacy of variants in psychosocial treatment service delivery that allow flexibility for parental preferences compared with those that do not. | 5 | 4
For people age 6 years or older with ADHD, which specific sociodemographic, baseline clinical characteristics, and neurobiological features predict a positive treatment response with respect to patient outcomes? | 5 | 3

ADHD = attention deficit hyperactivity disorder

### Highest Priority Research Needs: PICOTS Information and Considerations of Potential Research Designs

For each of the highest priority research needs below, we have stated the need in the form of a research question, highlighted key points of the stated need, applied a PICOTS framework (indicating the population, intervention, comparator, outcome, time, and setting variables), and described considerations for potential research designs. Some needs address methodological rather than intervention issues and did not squarely fit into a PICOTS framework; in these instances, we have indicated that the column is not applicable (N/A). This top tier of research needs should be considered as a whole, without any particular ranking within this group implied.

When used in the following PICOTS frameworks to describe “setting,” the term “clinic” indicates a private clinic (either pediatric or psychiatric), while the term “community” indicates a community clinic (with uninsured or under-insured patients, again either pediatric or psychiatric). Stakeholders emphasized the need for the settings to be clinics similar to where most patients are seen, rather than academic health centers, laboratory classroom settings, or academic day care centers.

Research design considerations should be focused on feasibility and reducing bias as much as possible. We offer some considerations of potential research designs below each research need and PICOTS framework. For each potential research design we considered the following: advantages of study design for producing a valid result; resource use, size, and duration; availability of data and ability to recruit; ethical, legal, and social issues. These considerations are intended to raise issues for teams planning to address these research needs, and are not meant to be prescriptive.

Sample size is another important consideration in planning future research. Since sample size issues are common across many research needs, we have consolidated a discussion of sample size issues after the detailed descriptions of each research need. The sample size required for trials will depend on multiple factors, with 250 to more than 1,000 subjects required to test many proposed research needs.

#### Research Need

- For people of all ages diagnosed with ADHD, what are the most accurate, brief standardized tools for diagnosis and outcome measurement that can be administered in generalizable practice settings and used on a repeated basis, integrated into clinical care?

Both the review and stakeholders emphasized the need for feasible and validated identification and management tools that are practical for use in the real-world clinic setting. One stakeholder emphasized the need for validated brief social functioning and peer interaction measures, specifically. A limitation is that a clear reference standard does not exist for social functioning measures.

P | I | C | O | T | S
All ages Diagnosed with ADHD | N/A | Feasible tools would be compared with reference standards for diagnosis, outcomes | Validation of instrument compared with reference standard | N/A | a. Epidemiological and naturalistic research settings; b. Clinical trials (efficacy); c. Practice-based research settings (effectiveness)

ADHD = attention deficit hyperactivity disorder; C = comparators; I = interventions; N/A = not applicable; O = outcomes; P = populations; S = settings; T = timeframes

##### Considerations for Potential Research Designs

###### Psychometric Testing

This type of rigorous evaluation would be an appropriate consideration for development of feasible and practical tools for use in diverse real-world clinical settings (clinical trials, practice-based research settings), particularly, for collecting adequate social functioning and peer interaction data. The preparation for such testing might require multiple steps, some qualitative and some quantitative, before some of the relevant tools are ready for validation in these settings.

- Advantages of study design for producing a valid result
  ◦ These types of research designs can produce valid and reproducible results when conducted with appropriate measures to ensure an unbiased assessment of the tools being compared, such as randomization of order in which each tool is applied. Limitations include availability of feasible assessment tools and availability of a reference standard or validation.
- Ability to recruit/availability of data
  ◦ Given the varied settings in which ADHD is treated as well as the prevalence of this disorder, recruitment issues are minimal for most settings.
- Resource use, size, and duration
  ◦ For primary data collection of this type, resource use and size are moderate and sample sizes needed depend on the number of items for the brief instruments. Brevity of measurement instruments will be key; use of computerized adaptive methods is a promising approach.
- Ethical, legal, and social considerations
  ◦ Ethical, legal, and social considerations are minimal given there is not an intervention. Standard privacy and confidentiality issues and considerations are required.

#### Research Need

- For children less than 6 years old with disruptive behavior disorder or ADHD, what is the comparative efficacy, effectiveness, and harmfulness of the available pharmacological treatments, singularly or in combination with other pharmacologic interventions?

This need focuses on pharmacologic interventions, either as a monotherapy or as a combination of pharmacologic agents, and broadly considers as key outcomes both the potential benefits and harms of interventions. We have identified key clinical and adverse events outcomes as reported in the draft review, which is limited by the variables reported in the published trials. ADHD, by nature, is represented by outcomes that are multifaceted. Stakeholders noted the need for greater information for each of these outcomes, and in particular noted a dearth of information regarding social functioning. Future studies might consider different or additional outcomes.

P | I | C | O | T | S
Age < 6 years Diagnosed with ADHD or disruptive behavior disorder | Pharmacological treatments, as single agent and/or medication combination | Other single or combined pharmacological treatments (e.g., stimulants vs. nonstimulants) | Outcomes for children and parents^*^ | Months/Years | Private clinic, community clinic, school, home

ADHD = attention deficit hyperactivity disorder; C = comparators; I = interventions; O = outcomes; P = populations; S = settings; T = timeframes

* Outcomes for children and parents include change in ADHD symptoms, social functioning, emotional regulation, executive functioning, treatment adherence, behavior problems, global functioning, academics, and parent competence, and harms, such as behavioral side effects, sleep difficulties, appetite/metabolic concerns, and cardiovascular changes.

##### Considerations for Potential Research Designs

###### Randomized Controlled Trials

The strongest study design as regards validity is the randomized trial, to examine effectiveness of medication compared with placebo, in situations where current strength of evidence is low or insufficient, as well as comparative effectiveness of agents with each other.

- Advantages of study design for producing a valid result
  ◦ Randomized controlled trials (RCTs) will most completely control for selection bias and differential characteristics in treatment studies.
- Ability to recruit/availability of data
  ◦ Recruitment into RCTs can be challenging, but given the current use of these treatments in the younger population and the uncertainty regarding their effectiveness, multisite trials should be feasible.
- Resource use, size, and duration
  ◦ Multisite, community-based trials will be optimal regarding assessment of treatment effectiveness, and therefore resource-intensive. See the following section regarding sample size estimates. Multisite studies will require careful training to assure consistency of intervention as well as analysis for site effect. Duration of the study would be several years at minimum.
- Ethical, legal, and social issues
  ◦ Young children are a vulnerable population, and careful informed consent will need to occur, but given the uncertainty regarding treatment choice in this population, high-quality trials are needed.

###### Retrospective Cohort Studies

Given the large sample size needed to detect relatively rare harms, prospective or retrospective cohort studies would be more feasible in assessing those outcomes.

- Advantages of study design for producing a valid result
  ◦ Cohort studies may be larger, but are prone to selection bias since providers and families both choose and are aware of treatment. However, the ability to monitor generalizable populations allows sufficient power to detect uncommon harms. Propensity scoring or similar methods should be used for balancing on baseline characteristics.
- Ability to recruit/availability of data
  ◦ Retrospective cohort studies of administrative or electronic health record data, which allows following large numbers of subjects over time. Such databases are becoming more commonly available and improving in quality. Such secondary data, however, may not be optimal for examination of drug benefits, which generally requires patient or patient derived information.
- Resource use, size, and duration
  ◦ Resources required for secondary data analysis or meta-analysis at the individual level would be much less.
- Ethical, legal, and social issues
  ◦ Data security and participant privacy/confidentiality issues require additional attention when obtaining data from other research groups. Pooling individual data across trials may raise issues of intellectual property, but other fields have been able to accomplish such tasks.

###### Meta-analysis of Individual Participant Data (MIPD)

If data were available and appropriate, meta-analysis of individual participant data might add to these analyses.

- Advantages of study design for producing a valid result
  ◦ In an MIPD, individual data from existing studies are brought together using harmonized definitions, and reanalyzed, providing greater statistical power than the individual trials. Pooling data from multiple studies allow analysis of heterogeneous populations and increased power in analyses.
- Ability to recruit/availability of data
  ◦ Eleven trials of pharmacologic interventions were reported in the meta-analysis, but there may be data availability issues regarding the ability to pool the information.
- Resource use, size, and duration
  ◦ Resources required for secondary data analysis or meta-analysis at the individual level would be much less.
- Ethical, legal, and social issues
  ◦ Data security and participant privacy/confidentiality issues require additional attention when obtaining data from other research groups. Pooling individual data across trials may raise issues of intellectual property, but other fields have been able to accomplish such tasks.

#### Research Need

- For children less than 6 years old with disruptive behavior disorder or ADHD, what is the comparative efficacy and effectiveness for patient outcomes of differing combinations of psychosocial and pharmacological treatments for those who either are [underlined: initiating treatment] with psychosocial therapies or who have [underlined: not improved on their current therapy]? Are there discrete patient-level predictors that favor a particular treatment strategy?

This need addresses the question of the most effective combination of pharmacologic and psychosocial interventions, as either the initial line of treatment or as the option following failure of the current treatment. The assumption is that the standard of practice when initiating treatment for patients younger than 6 years old with ADHD is to begin psychosocial treatment, but the question of interest for those beginning treatment is whether psychosocial treatment or pharmacologic treatment, singularly or in combination, is the optimal initial treatment. Initial combination treatments would be compared with initial treatments, and combinations after treatment failures would be compared with other combinations after treatment failures. This question is a complex one, involving a variety of potential combinations.

P | I | C | O | T | S
Age < 6 years Diagnosed with ADHD or at risk for ADHD or diagnosed with disruptive behavior disorder (including Oppositional defiant disorder [ODD] and Conduct disorder [CD] according to the Diagnostic and Statistical Manual [DSM]) | Initial treatment with psychosocial and/or pharmacologic treatments or Addition of a psychosocial and/or pharmacological treatment to an existing treatment after treatment failure | Initial treatment with psychosocial and/or pharmacologic treatments or Continuation of existing treatment without addition of psychosocial and/or pharmacologic treatment or switch to different treatment | Outcomes for children and parents^*^ | Months/Years | Private clinic, community clinic, school, home

ADHD = attention deficit hyperactivity disorder; C = comparators; I = interventions; O = outcomes; P = populations; S = settings; T = timeframes

* Outcomes for children and parents include change in ADHD symptoms, behavior problems, social functioning, emotional regulation, executive functioning, treatment adherence, global functioning, academics, and parent competence.

##### Considerations for Potential Research Designs

###### Randomized Controlled Trials

RCTs would provide information on comparative efficacy and effectiveness for patient outcomes of differing combinations of psychosocial and pharmacological treatments.

- Advantages of study design for producing a valid result
  ◦ RCTs of variants of pharmacologic interventions are an ideal consideration because such designs can allow isolation of causal inferences related to pharmacological intervention being tested. Multiple-armed trials would allow testing of several hypotheses regarding relative efficacy of singular or combination treatment components.
  ◦ RCTs provide ideal control for selection biases that can invalidate inferences made related to treatment. However, strong emphasis on controlling baseline covariates across treatment conditions and randomization can limit generalizability of results to other less controlled settings.
- Ability to recruit/availability of data
  ◦ Given the relatively high prevalence of ADHD for this age group, the availability of potential eligible patients is good. The specifics of selection criteria (e.g., prior treatment history, comorbid diagnoses, or concomitant medications) would affect the ease of recruitment.
- Resource use, size, and duration
  ◦ Costs would be significant for such trials because they would be resource intensive and require both medication and psychosocial interventions, with a total sample size of N=840 with n = 210 per treatment arm) (Table 4). Also, trials to evaluate harms will require lengthy duration and large sample sizes.
- Ethical, legal, and social issues
  ◦ Trials will require careful informed consent for this vulnerable population. Documentation of harm or adverse effects requires data and safety monitoring if evidence of significant benefit or harm is found.

Table 3 Sample size required to detect treatment effects in a 2x2 factorial design

Effect | Effect Size | Approximate n per Treatment arm | N
Treatment main effect | 0.20 | 395 | 1580
Treatment main effect | 0.35 | 130 | 520
Treatment main effect | 0.50 | 70 | 280
Treatment main effect | 0.80 | 30 | 120
Interaction | 0.20 | 800 | 3200
Interaction | 0.35 | 260 | 1040
Interaction | 0.50 | 130 | 520
Interaction | 0.80 | 50 | 200

Table 4 Sample size required to detect treatment effects in a 2x2 factorial design with repeated measures

% Variation Between Individuals | Effect | # Repeated Measures | Approx. n per Treatment arm | N
20 | Treatment main effect | 2 | 215 | 860
20 | Treatment main effect | 3 | 210 | 840
20 | Treatment main effect | 5 | 170 | 680
20 | Treatment main effect | 7 | 135 | 540
20 | Treatment main effect | 9 | 115 | 460
20 | Interaction | 2 | 400 | 1,600
20 | Interaction | 3 | 420 | 1,680
20 | Interaction | 5 | 340 | 1,360
20 | Interaction | 7 | 260 | 1,040
20 | Interaction | 9 | 220 | 880
50 | Treatment main effect | 2 | 140 | 560
50 | Treatment main effect | 3 | 135 | 540
50 | Treatment main effect | 5 | 110 | 440
50 | Treatment main effect | 7 | 90 | 360
50 | Treatment main effect | 9 | 70 | 280
50 | Interaction | 2 | 260 | 1,040
50 | Interaction | 3 | 250 | 1,000
50 | Interaction | 5 | 210 | 840
50 | Interaction | 7 | 170 | 680
50 | Interaction | 9 | 140 | 560
80 | Treatment main effect | 2 | 60 | 240
80 | Treatment main effect | 3 | 60 | 240
80 | Treatment main effect | 5 | 45 | 180
80 | Treatment main effect | 7 | 40 | 160
80 | Treatment main effect | 9 | 30 | 120
80 | Interaction | 2 | 110 | 440
80 | Interaction | 3 | 110 | 440
80 | Interaction | 5 | 80 | 320
80 | Interaction | 7 | 70 | 280
80 | Interaction | 9 | 60 | 240

#### Research Need

- For people of all ages diagnosed with ADHD (and especially adolescents and adults), what methods provide the most useful data collection, assessment of prevalence, case identification, and outcomes measurements for studies involving epidemiologic surveys and administrative databases?

This question is primarily one of research methods and highlights the need for tools to facilitate the efficient study of large-scale datasets, as well as conduct of primary data collection through surveys. Intervention and Treatment considerations are not a direct focus of this research need; rather, they are key in how to apply the findings that might result from acquiring these tools. The Setting consideration should maximize generalizability and reflect the population of children and young adults. Although a variety of tools are available, stakeholders indicated a concern that the datasets available may not contain the necessary data to capture the relevant information (e.g., diagnosis or clinical status). This need highlights the absence of validated, feasible tools for use in epidemiologic surveys and for secondary analyses of administrative or clinical datasets.

P | I | C | O | T | S
All ages Diagnosed with ADHD | N/A | a. Education system,; b. Health insurance,; c. Providers | Evidence-based performance measures (Methods) | N/A | Population-based surveys

ADHD = attention deficit hyperactivity disorder; C = comparators; I = interventions; N/A = not applicable; O = outcomes; P = populations; S = settings; T = timeframes

##### Considerations for Potential Research Designs

One potential approach for this research need is not a research design, but rather a consideration for forming an expert panel to examine data sources such as third-party payer (e.g., private health insurance and state Medicaid) databases, electronic medical records, school records, and large epidemiological studies of children’s health. The panel could bring together experts with knowledge of diagnostic codes, variables in databases, and access issues for school and medical records; epidemiologists and other researchers with knowledge of how to standardize data and use multiple data sources; and diagnosticians who specialize in screening and diagnosing ADHD in people of all ages. Consultation with privacy and information technology experts will also be helpful.

###### Expert Panel

- Advantages of study design for producing a valid result
  ◦ A precondition for addressing this future research need would be collaborative relationships between researchers and entities that manage databases that could capture and contain the necessary information for assessing prevalence of ADHD, identifying undiagnosed cases, and determining appropriate outcome measures for people receiving treatment. Issues of data availability and data linkage will be as important as diagnostic criteria. The outcome would be consensus regarding data to be collected to address these prevalence and outcome research needs.
- Ability to recruit/availability of data
  ◦ Recruiting experts for participation should be a relatively easy pursuit. Scheduling and managing deliverables for a large group could present challenges.
- Resource use, size, and duration
  ◦ Funding would need to be provided to an entity to provide staff and logistic support to the panel and it could involve travel costs for in-person meetings. Significant effort would be required to present information to this diverse group efficiently, as well as group process management to achieve consensus. A potential disadvantage is that an expert panel often takes a considerable amount of time to reach consensus and produce viable recommendations that can be put in to practice.
- Ethical, legal, and social issues
  ◦ The panel could consider the ethical, legal, and social issues of secondary data analysis of large datasets with potentially identifying information and access to school and medical records. Panel members should include ethics and legal experts.

###### Secondary Data Analyses of Epidemiological and Treatment Studies

- Advantages of study design for producing a valid result
  ◦ Consensus regarding methods for establishing diagnosis is a precondition for a major effort to conduct these secondary analyses. The use of diagnostic codes alone from administrative databases has, at best, unclear specificity in ADHD. For example, is a single diagnostic code sufficient to accurately identify ADHD, or should diagnosis on at least two occasions be required? A potentially sensitive and specific set of criteria could be developed through consensus development as described above. Another approach would be to link primary data collected from a registry as a reference standard to administrative data to examine the diagnostic characteristics of information from such administrative or other secondary data. Pooling data from observational studies allows for increased sample size and analysis of heterogeneous presentations of ADHD seen in various settings. Another advantage of secondary analytic studies that pool data from epidemiological and treatment samples is that sensitivity analyses could be conducted to determine which are the best capture methods and which are the most sensitive to picking up change due to an intervention. Subset analyses to examine the sensitivity of prevalence methods across demographic subpopulations will be important.
- Ability to recruit/availability of data
  ◦ Success depends on the availability of large, comparable datasets. Many datasets exist, but the stakeholders raised concerns about the utility of the existing datasets to identify cases and assess prevalence. The consensus discussion noted above might clarify how useful the available data are.
- Resource use, size, and duration
  ◦ Resources needed for such studies would be moderate, but the benefits would assist many future treatment efforts. A key goal will be to identify efficient methods of data collection and analysis for the future.
- Ethical, legal, and social issues
  ◦ While secondary data analyses generally do not incur major ethical or legal issues, examination of the various components of ADHD may involve linking of administrative health data with, for example, school data. This procedure may require extensive consideration regarding need for parental consent in some settings and/or data use agreements prior to beginning data analysis.

#### Research Need

- For children less than 6 years old with disruptive behavior disorder or ADHD, what is the comparative efficacy and effectiveness of specific psychosocial treatments alone compared with pharmacological treatments alone or in combination with psychosocial treatments for patient outcomes?

Individual treatment and a combination of the two are relatively common interventions. While significant literature exists on the efficacy of psychosocial treatments, we currently know little regarding the comparative benefit of such behavioral and educational interventions compared to either medication treatment alone or to a combination of the two treatment type.

P | I | C | O | T | S
Age < 6 years Diagnosed with ADHD or at risk for ADHD or diagnosed with Disruptive Behavior Disorder (including ODD and CD by DSM) | Psychosocial interventions alone (including parent training and school-based interventions) | Pharmacological treatments, alone or in combination with psychosocial treatments | Outcomes for children and parents^*^ | 6 Months/1 Year | Private clinic, community clinic

ADHD = attention deficit hyperactivity disorder; C = comparators; CD = conduct disorder; DSM = Diagnostic and Statistical Manual; I = interventions; O = outcomes; ODD = oppositional defiant disorder P = populations; S = settings; T = timeframes

* Outcomes for children and parents include change in ADHD symptoms, social functioning, emotional regulation, executive functioning, treatment adherence, behavior problems, global functioning, academics, and parent competence.

##### Considerations for Potential Research Designs

###### Randomized Controlled Trials

For this research need, randomized trials could be designed to test various components in a 2x2 matrix of psychosocial treatment variants (parent training, school-based intervention, combination, or pharmacological).

- Advantages of study design for producing a valid result
  ◦ Randomized trials of variants of pharmacologic interventions are an ideal consideration as such designs can allow isolation of causal inferences related to the intervention being tested. Multiple-armed trials would allow testing of several hypotheses regarding relative efficacy of singular or combination treatment components. Similarly, such study designs can address any additive benefits or harms associated with addition of medication to a psychosocial intervention, compared with a psychosocial intervention alone. RCTs provide ideal control for selection bias. Community- based study settings and broad eligibility criteria will be critical to assure generalizability to the population of young children with the condition.
- Ability to recruit/availability of data
  ◦ ADHD is a common condition in this age group with uncertainty regarding treatment choice; the study designs here are CERs in which all arms receive some treatment. This will aid recruitment.
- Resource use, size, and duration
  ◦ This design approach would be resource intensive, as differences among the groups may be difficult to detect without a sufficiently large sample size (N =840; n = 210 per treatment arm) (Table 3). However, ADHD is common and currently incurs large health care and social costs, justifying an adequately powered trial. Multisite trials will be needed, increasing management complexity of the studies. Assessment of outcomes such as school achievement will require follow-up of several years.
- Ethical, legal, and social issues
  ◦ Young children are a vulnerable population and careful informed consent will need to occur, but given the uncertainty regarding treatment choice in this population, high-quality trials are needed.

#### Research Need

- For people age 6 years or older with ADHD, what are the comparative long-term outcomes for the available psychosocial and pharmacological treatments?

This need highlights the import noted by both the review and the stakeholders on the need for longer-term outcome data to guide decisionmaking. Outcomes of interests would involve both benefits, including educational measures that encompass academic outcomes, and harms. The definition of “long term” is not clear, but would likely be multiple years.

P | I | C | O | T | S
Age ≥ 6 years Diagnosed with ADHD | Psychosocial and/or pharmacological treatments | Other psychosocial and/or pharmacological treatments | Outcomes for children and parents^*^ | Months/Years | Private clinic, community clinic, school, home

ADHD = attention deficit hyperactivity disorder; C = comparators; I = interventions; O = outcomes; P = populations; S = settings; T = timeframes

* Outcomes for children and parents include change in ADHD symptoms, social functioning, emotional regulation, executive functioning, treatment adherence, behavior problems, global functioning, academics, and parent competence, and adverse events/harms.

##### Considerations for Potential Research Designs

###### Extensions of RCTs

This research design could be applied to current or future RCTs by adding extension phases in which treatments are continued for some or all of the trial participants beyond the original timeline of the trial.

- Advantages of study design for producing a valid result
  ◦ This research design is likely to yield long-term data on health outcomes and harms for various treatments. Significant crossover may occur over time, reducing the statistical power of the result. At some point, the original trial becomes similar to an observational cohort.
- Ability to recruit/availability of data
  ◦ Recruitment might depend on the overall attrition in the original RCT and retention over time is an issue in an extension period. Data could be biased toward those who experience benefits from treatments and in some cases, an appropriate comparison group may be lacking.
- Resource use, size, and duration
  ◦ Extension studies could be expensive and resource intensive depending on the intervention and data collection methods. The optimal duration for observing long-term outcomes is not known, but generally 3 to 5 years is considered the minimum.
- Ethical, legal, and social considerations
  ◦ These studies would be most likely to compare active controls or to observe a group of people who are all receiving the same treatment because there are ethical concerns about withholding potentially beneficial treatment from a control group.

###### Retrospective Cohort Study

- Advantages of study design for producing a valid result
  ◦ This research design has the potential to yield information about associations between treatments and outcomes or adverse events. Information may be available from more generalizable populations.
  ◦ However, conclusions about causation must be made with caution. Because treatments are not randomized in this study design, a risk of bias exists that would need to be addressed in any analysis of the data. Many patients and providers are likely to switch treatments if patients experience harmful side effects early in treatment, making it difficult to assess long-term outcomes. Potential confounders (e.g., co-interventions, parental preferences) might not have been measured.
- Ability to recruit/availability of data
  ◦ Providers who treat people with ADHD could readily identify their patients with a diagnosis of ADHD and match them with appropriate controls and conduct retrospective records reviews.
  ◦ However, as noted by the stakeholders, databases and medical records may lack the necessary data to sufficiently identify people with ADHD solely by reviewing records or mining databases. In situations where cases are known, the medical records may lack information about outcomes or adverse events. Access to adequate educational/academic outcome data could be difficult in a retrospective study.
- Resource use, size, and duration
  ◦ Relative to an RCT, this study design would require fewer resources and take less time.
  ◦ However, the sample size would have to be large to detect an association between specific treatments and outcomes, which would include measures of clinical benefits or harms.
- Ethical, legal, and social considerations
  ◦ Issues of informed consent or waiver of consent would need to be negotiated. Linking of data across clinical and school records would require data use agreements.

#### Research Need

- Among children less than 6 years old with disruptive behavior disorder or ADHD, what is the relative/comparative efficacy of key components of psychosocial treatment programs? These might include the relative efficacy of specific parent training compared with treatment components targeting the child, or the efficacy of variants in psychosocial treatment service delivery that allow flexibility for parental preferences compared with those that do not.

In this research need, stakeholders emphasized the importance of identifying what key parts of the psychosocial intervention were associated with improved outcomes, since these interventions currently contain a number of ‘bundled’ components. Specifically, they described dropout as a substantial concern and highlighted the need for a better understanding how adherence relates to outcomes. In particular, they indicated that parental preference may be an influential factor. Given the complexity of the study design, we recommend a randomized trial design; other study types would have sufficient issues with selection bias and intervention description, making the ability to achieve a valid result problematic.

P | I | C | O | T | S
Age < 6 years Diagnosed with ADHD or at risk for ADHD or diagnosed with Disruptive Behavior Disorder (including ODD and CD by DSM) | Variety of components as a part of a psychosocial treatment program | A different collection of components of a psychosocial treatment program so as to allow isolation of the effect of specific components | Outcomes for children and parents^*^ | Months/Years | Private clinic, community clinic, school, home

ADHD = attention deficit hyperactivity disorder; C = comparators; CD = conduct disorder; DSM = Diagnostic and Statistical Manual; I = interventions; O = outcomes; ODD = oppositional defiant disorder P = populations; S = settings; T = timeframes

* Outcomes for children and parents include change in ADHD symptoms, social functioning, emotional regulation, executive functioning, treatment adherence, behavior problems, global functioning, academics, and parent competence.

##### Considerations for Potential Research Designs

###### Randomized Controlled Trials

- Advantages of study design for producing a valid result
  ◦ An RCT designed to test various components of a 2x2 matrix of psychosocial treatment variants, such as parent training, school-based intervention, or a combination of psychosocial treatments, while the comparison condition is centered on psychosocial treatment that includes flexibility with treatment manual to accommodate parental preferences would isolate treatment effects and the influence of parental preferences. See Table 3 in sample size section. Since all children would receive an active intervention, the effect of both interventions might be similar. An important consideration would be identification of an effect size between the groups that would be of clinical and policy significance prior to study initiation to reduce risk of type 2 error.
- Ability to recruit/availability of data
  ◦ ADHD is a common condition in this age group, and acceptability of educational and psychosocial interventions may be good. Fidelity of the intervention across sites and dropout will represent significant challenges to conduct of these trials. Multisite trials will be needed.
- Resource use, size, and duration
  ◦ This design option would require a sample size of at least N=520 with about n=130 participants per intervention arm (Table 3), similar to the sample size used in the MTA study (579 children among 4 treatment groups).22 Thus, given the number of participants and variety of treatment approaches (parent training, classroom, pharmacological, parental preference variant), this option would be expensive. ADHD is a common condition with significant treatment and social costs, justifying the need for such trials. Particularly attractive would be comparison of relatively simple, very standard interventions with interventions that are modified based on parental preference. The latter interventions are more complex and resource intensive to perform, making them important issues for evaluation.
- Ethical, legal, and social considerations
  ◦ Children would all receive treatment, reducing any ethical concerns regarding lack of equipoise.

#### Research Need

- For people age 6 years or older with ADHD, which specific socio-demographic, baseline clinical characteristics, and neurobiological features predict a positive treatment response with respect to patient outcomes?

Note: Sociodemographic and baseline clinical characteristics include: gender, socioeconomic status, race, comorbidity with other psychiatric disorders, ADHD subtypes, comorbid developmental disorders, comorbid learning disabilities, language impairments, reading or mathematics disorders. The goal, in contrast to several other future research needs, is not to determine an overall effectiveness of treatment, but rather identify predictors of response to a treatment. Neurobiological features include: genetic variants and neuroimaging abnormalities. This need reflects stakeholders’ interest in finding variables that might help tailor a recommendation of a particular treatment from which an individual would be more likely to receive benefit. Analyses would involve consideration of moderators and mediators.

P | I | C | O | T | S
Age ≥ 6 years Diagnosed with ADHD | Any treatment for ADHD | a. Inter-subgroup comparisons (e.g., male versus female); b. Subgroup versus all ADHD subjects( e.g., comorbidity versus no comorbidity, inattentive subtype versus combined subtype);; c. Correlation with quantitative traits (e.g., neuropsychological dysfunction) | Outcomes for children and parents^*^ | Months/Years | Private clinic, community clinic, school, home

ADHD = attention deficit hyperactivity disorder; C = comparators; I = interventions; O = outcomes; P = populations; S = settings; T = timeframes

* Outcomes for children and parents include change in ADHD symptoms, behavior problems, social functioning, emotional regulation, executive functioning, treatment adherence, global functioning, academics, and parent competence.

##### Considerations for Potential Research Designs

###### Secondary Analysis of Existing Cohort Studies and Randomized Trials

- Advantages of study design for producing a valid result
  ◦ Current published trials have had limited generalizable information regarding predictors of treatment response. Requests to investigators regarding additional information could be investigated. Secondary analyses of trials, which generally have higher quality and more standard data collection, would yield more valid results. Secondary analyses of existing cohort studies, in which patient characteristics are more reflective of the population affected by ADHD, will be more generalizable but likely have more incomplete data and potential selection bias.
- Ability to recruit/availability of data
  ◦ Completeness of data across different trials may be a challenge, and the willingness of researchers to share data can be an issue vis-à-vis control and intellectual property. Support of funders and professional societies can be valuable in accomplishing these tasks. The ability to combine data across databases will depend on how much missing data are present, and whether the manner of data collection is heterogeneous.
- Resource use, size, and duration
  ◦ These analyses are much less resource intensive than new, prospective data collection. Significant effort, however, must take place early on in the process to determine the feasibility of drawing inferences from data collected by different investigators from somewhat different populations. Duration of the study is modest, but experience has demonstrated that often at least a year is needed to assemble these secondary data from multiple sources.
- Ethical, legal, and social considerations
  ◦ Since new data are not collected, only modest ethical issues are present. However, data control and intellectual property issues often require negotiation. Linkage of databases, especially those that contain genetic information, requires significant human subjects and data use agreement discussion.

###### Consensus Conference

A recommendation, not tied to a specific study design, would be researchers’ consensus regarding routine collection of patient baseline clinical characteristics for future studies, which would greatly facilitate progression toward more patient-centered and personalized care for ADHD. This discussion would involve not just the types of variables collected, but also the specific categories and measures. Consensus across research organization and recommendations by funders would be helpful in advancing this research need. A consensus conference would be useful to accomplish this aim, since many of the problems enumerated above are due to the lack of standard data collection across studies. All such consensus efforts trade off complete data availability with cost of additional data collection. Brief, but consistent data collection regarding these issues across trials would greatly aid addressing this research need.

#### Sample Size Calculations

Power analyses were conducted based on a few hypothetical designs for randomized trials that would fit one or more of the research needs outlined in this report. Some of the high-priority research needs involve tests of larger effects (e.g., treatment main effects, comparisons to usual care), whereas others involve comparisons of smaller effects (e.g., treatment interactions, comparisons between treatments). Also, the earlier comparative effectiveness review found a wide range of effect sizes for medications and psychosocial interventions compared with no treatment, to treatment as usual, or to each other. Therefore, rather than make strict assumptions about the treatments being tested, we estimated the sample size required for testing both main effects and interaction effects, and we allowed for a range of effect sizes (0.2, 0.35, 0.5, 0.8). We focus on the 2x2 factorial design since it was a component of several high-priority research needs.

These power analyses were conducted using simulations.23 Table 3 shows the sample size required to detect treatment main effects and interaction effects on a normally distributed continuous outcome (e.g., pretest to post-test change) with a 2x2 factorial design in which individuals are randomly assigned to treatment. Each sample size was determined by generating 2,000 simulated datasets and identifying the minimum sample size required to detect the given effect with 80 percent power, 5 percent Type I error, and a 2-tailed test. The data generation model assumed equal effect sizes for the two treatments and their interaction:

Y_i_ = μ + d*Z1_i_ + d*Z2_i_ + d*Z1_i_*Z2_i_ + e_i_

where Y_i_ is the outcome for person i, μ is the pre-treatment mean, d is the size of the two treatment main effects and their interaction effect (relative to the control group standard deviation on the change score), Z1_i_=1 if person i received treatment 1 and Z1_i_=0 otherwise, Z2_i_=1 if person i received treatment 1 and Z2_i_=0 otherwise, and e_i_ is the residual for person i.

To detect treatment main effects, a 2x2 factorial design requires the same sample size per treatment arm as a two-group study. (The factorial design simply has four treatment arms in order to detect two different treatment main effects.) To detect an interaction between two treatments (or between a treatment and an effect modifier), the required sample is about twice as large as the sample required to detect a treatment main effect of the same size (Table 3). Of course, detecting a smaller treatment effect requires a larger sample.

Table 4 shows that taking more than two measurements of the outcome variable during the intervention period reduces the required sample size. These results are based on simulations similar to those described above. We assumed a constant effect size of 0.35 (from the first measurement occasion to the last) for the treatment main effects and their interaction.

In a trial with repeated measures, the amount of between-subject (versus within-subject) variation in the outcome variable affects projections of the required sample size. Having a larger proportion of variation between subjects corresponds to less residual error and easier detection of treatment effects. The proportion of variation that is between subjects depends on the outcome being studied, the reliability of the outcome measures, and the amount of time between measurements. We used a range of values (0.2, 0.5, 0.8).

The data generation model for repeated measures designs included a random intercept to account for the dependence among multiple observations per person. The model assumed that there was no main effect of time on the outcome:

Y_it_ = μ + (d/(T-1))*Z1_i_*time_it_ + (d/(T-1))*Z2_i_*time_it_ + (d/(T-1))*Z1_i_*Z2_i_*time_it_ + μ_0i_ + e_it_

where Y_it_ is the outcome for person i at time t, μ is the pretreatment mean, d is the size of the two treatment main effects and their interaction effect (relative to the control group standard deviation on the dependent variable), T is the number of measurement occasions, Z1_i_=1 if person i received treatment 1 and Z1_i_=0 otherwise, Z2_i_=1 if person i received treatment 1 and Z2_i_=0 otherwise, time_it_={1,…T} is time since the beginning of the study, u_0i_ is a person-level random intercept, and e_it_ is the residual for person i at time t.

As shown in Table 4, increasing the number of measurement occasions reduces the sample size required to detect a treatment effect of a given size. In deciding on the number of measurement occasions in a study, one must weigh the cost of adding participants against the cost of additional data collection. (Because the two data generation models are based on different assumptions and have different denominators for the effect size, the sample size requirements for a design with d=0.35 and two repeated measures are different in Table 4 than in Table 3).