# References

1 Attention Deficit Hyperactivity Disorder: Effectiveness of Treatment in At-risk Preschoolers; Long-Term Effectiveness in All Ages; and Variability in Prevalence, Diagnosis, and Treatment (Draft). Rockville, MD. Agency for Healthcare Research and Quality. in press http://effectivehealthcare.ahrq.gov/.
2 Miller AR, Lalonde CE, McGrail KM, et al. Prescription of methylphenidate to children and youth, 1990-1996. CMAJ. Nov. 27. 2001;165(11):1489-94. [pmid: 11762572].
3 Robison LM, Sclar DA, Skaer TL, et al. National trends in the prevalence of attention-deficit/hyperactivity disorder and the prescribing of methylphenidate among school-age children: 1990-1995. Clin Pediatr (Phila). Apr. 1999;38(4):209-17. [pmid: 10326176].
4 Safer DJ, Zito JM, Fine EM. Increased methylphenidate usage for attention deficit disorder in the 1990s. Pediatrics. Dec. 1996;98(6 Pt 1):1084-8. [pmid: 8951257].
5 Brownell MD, Yogendran MS. Attention-deficit hyperactivity disorder in Manitoba children: medical diagnosis and psychostimulant treatment rates. Can J Psychiatry. Apr. 2001;46(3):264-72. [pmid: 11320681].
6 Rappley MD, Gardiner JC, Jetton JR, et al. The use of methylphenidate in Michigan. Arch Pediatr Adolesc Med. Jun. 1995;149(6):675-9. [pmid: 7767425].
7 Achenbach TM, Dumenci L, Rescorla LA. Are American children's problems still getting worse? A 23-year comparison. J Abnorm Child Psychol. Feb. 2003;31(1):1-11. [pmid: 12597695].
8 Charach A, Cao H, Schachar R, et al. Correlates of methylphenidate use in Canadian children: a cross-sectional study. Can J Psychiatry. Jan. 2006;51(1):17-26. [pmid: 16491980].
9 Zito JM, Safer DJ, Valluri S, et al. Psychotherapeutic medication prevalence in Medicaid-insured preschoolers. J Child Adolesc Psychopharmacol. Apr. 2007;17(2):195-203. [pmid: 17489714].
10 Pliszka S. AACP Work Group on Quality Issues. Practice parameter for the assessment and treatment of children and adolescents with attention-deficit/hyperactivity disorder. J Can Acad Child Adolesc Psychiatry. 2007;46(7):894-921. [pmid: 17581453].
11 Greenhill LL, Posner K, Vaughan BS, et al. Attention deficit hyperactivity disorder in preschool children. Child Adolesc Psychiatr Clin N Am. Apr. 2008;17(2):347-66. ix. [pmid: 18295150].
12 Simon V, Czobor P, Balint S, et al. Prevalence and correlates of adult attention-deficit hyperactivity disorder: meta-analysis. Br J Psychiatry. Mar. 2009;194(3):204-11. [pmid: 19252145].
13 Jadad AR, Boyle M, Cunningham C, et al. Treatment of attention-deficit/hyperactivity disorder. Evid Rep Technol Assess (Summ). Nov. 1999;(11):i-viii. 1. 341. [pmid: 10790990].
14 Murray DW. Treatment of preschoolers with attention-deficit/hyperactivity disorder. Curr Psychiatry Rep. Oct. 2010;12(5):374-81. [pmid: 20676944].
15 Wilens TE, Faraone SV, Biederman J. Attention-deficit/hyperactivity disorder in adults. JAMA. Aug. 4. 2004;292(5):619-23. [pmid: 15292088].
16 Kooij SJ, Bejerot S, Blackwell A, et al. European consensus statement on diagnosis and treatment of adult ADHD: The European Network Adult ADHD. BMC Psychiatry. 2010;10:67. [pmid: 20815868].
17 Chavez B, Sopko MA Jr, Ehret MJ, et al. An update on central nervous system stimulant formulations in children and adolescents with attention-deficit/hyperactivity disorder. Ann Pharmacother. Jun. 2009;43(6):1084-95. [pmid: 19470858].
18 Ipser J, Stein DJ. Systematic review of pharmacotherapy of disruptive behavior disorders in children and adolescents. Psychopharmacology (Berl). Mar. 2007;191(1):127-40. [pmid: 16983542].
19 Centers for Disease Control and Prevention(CDC): Mental health in the United States. Prevalence of diagnosis and medication treatment for attention-deficit/hyperactivity disorder--United States, 2003. Morbid Mortal Week Rep. Sep. 2. 2005;54(34):842-7. [pmid: 16138075].
20 Kratochvil CJ, Greenhill LL, March JS, et al. The role of stimulants in the treatment of preschool children with attention-deficit hyperactivity disorder. CNS Drugs. 2004;18(14):957-66. [pmid: 15584766].
21 Molina BS, Hinshaw SP, Swanson JM, et al. The MTA at 8 years: prospective follow-up of children treated for combined-type ADHD in a multisite study. J Am Acad Child Adolesc Psychiatry. May. 2009;48(5):484-500. [pmid: 19318991].
22 A 14-month randomized clinical trial of treatment strategies for attention-deficit/hyperactivity disorder. The MTA Cooperative Group. Multimodal Treatment Study of Children with ADHD. Arch Gen Psychiatry. Dec. 1999;56(12):1073-86. [pmid: 10591283].
23 Arnold BF, Hogan DR, Colford JM Jr, et al. Simulation methods to estimate design power: an overview for applied research. BMC Med Res Methodol. Jun. 20. 2011;11(1):94. [pmid: 21689447].
24 McKee PA, Castelli WP, McNamara PM, et al. The natural history of congestive heart failure: the Framingham study. N Engl J Med. Dec. 23. 1971;285(26):1441-6. [pmid: 5122894].
25 Curran PJ, Hussong AM, Cai L, et al. Pooling data from multiple longitudinal studies: the role of item response theory in integrative data analysis. Dev Psychol. Mar. 2008;44(2):365-80. [pmid: 18331129].