# Methods

## Identification of Evidence Gaps

We identified the initial evidence gaps from sections throughout the draft review that described limitations that prevented the authors from drawing conclusions about a research question.1 The project team then used information from the draft review regarding eligible evidence gaps, populations, interventions, comparators, outcomes, timeframes, and settings (PICOTS) to develop a table to show the relevant PICOTS for each evidence gap.

A preliminary list of evidence gaps (Appendix A) and an analytic framework (Figure 1) showing the relationships between the Key Questions, PICOTS elements, and components of the evidence gaps were presented to the stakeholders as part of their orientation materials and discussed at the first stakeholder call. During the first call, we invited stakeholders to comment on and make contributions to the list of evidence gaps. After receiving stakeholder input, project investigators revised the list of evidence gaps, and applied the PICOTS elements to the new and revised gaps to ensure that each gap addressed one or more populations, interventions, comparators, outcomes, timeframes, and settings within the scope of the review. The final list of evidence gaps and the analytic framework are presented above (Table 1 and Figure 1).

## Criteria for Prioritization

After the stakeholders had an opportunity to revise the list of evidence gaps, the project team developed an online prioritization exercise (Appendix B) and invited the stakeholders to rank the evidence gaps in order of priority. We encouraged the stakeholders to consider their own perspectives and the interests of their constituents along with a modified version of the Effective Health Care (EHC) Program Selection Criteria (Appendix C) and a list of ongoing studies relevant to the topics of the Comparative Effectiveness Review (CER) during the prioritization. The modified version of the EHC Program Selection Criteria emphasized the three elements that were most applicable to stakeholders considering future research needs on a topic already under review by the EHC. These elements were importance, desirability of new research/duplication, and potential impact. We did not ask the stakeholders to consider the other two elements of the EHC criteria, appropriateness and feasibility, at this juncture.

Before the prioritization exercise, the stakeholders also received a list of ongoing studies developed by the project team after reviewing titles and short descriptions of research studies obtained through searching online research registries. We searched clinicaltrials.gov, HSRProj, NIH RePORTER, and the International Clinical Trials Registry Project (ICTRP) to find relevant ongoing or recently completed research. Search strategies are shown in Appendix D. Two people from the research team independently reviewed each ongoing study title and abstract and applied the inclusion and exclusion criteria from the draft review to determine which studies might have met the inclusion criteria for the CER if they had been completed and published results before the CER cutoff date. During the first stakeholder call, the stakeholders reviewed the list of ongoing studies and provided feedback on its completeness and the relevance of the research studies to the existing evidence gaps. The purpose of this list was to help the stakeholders identify any potential evidence gaps that might be addressed by current research, and to use that information when considering how to prioritize the evidence gaps.

### Engagement of Stakeholders, Researchers, and Funders

Because identifying and engaging a diverse stakeholder panel are critical components of the future research needs (FRN) process, we identified a broad range of interests and potential stakeholders as one of the first steps in this project. We identified potential stakeholders in consultation with our Agency for Healthcare Research and Quality (AHRQ) Task Order Officer and during an internal planning meeting, to which we invited representatives from the Evidence-based Practice Center (EPC) that produced the draft review. During the meeting, we discussed potential stakeholders known to the experts on our team; we also asked the review authors for names of stakeholders that they had used in generating their review. Each potential stakeholder completed a statement of disclosure, was screened for apparent conflicts of interest, and approved by AHRQ prior to the first stakeholder call.

We sought a variety of individuals who represented one or more perspectives on the issues of attention deficit hyperactivity disorder (ADHD) such as patient and family advocacy groups; health care providers, including diagnosticians and treatment experts; educators for preschool and school-age children; researchers, including those with experience in pharmacology, psychiatry, education, epidemiology, and screening tools; state policymakers and payers of services; professional provider and educator organizations; individuals with knowledge of health services delivery systems or disparities among patients with ADHD; and research funders. The purpose of seeking these different perspectives was to produce a group that represented varied points of view on issues related to treatment, diagnosis, adverse events, and prevalence with respect to ADHD.

After developing a list of potential stakeholders, we sent invitations to individuals and organizations to identify representatives. We provided potential stakeholders with a brief description of the project, including their role and the amount of time we expected them to contribute.

The stakeholders contributed to this FRN project via email, conference calls, and Web-based prioritization activities. We planned two conference calls using GoToMeeting® and two rounds of a Web-based prioritization exercise with the stakeholder group. Prior to the first call, we sent orientation materials to the stakeholders. These materials included the executive summary of the draft review and a description of the FRN project and its goals. Stakeholders also received a meeting packet that included the preliminary list of evidence gaps, the modified EHC Program Selection Criteria, and a list of ongoing studies that were reviewed to determine if they meet the inclusion criteria for the review.

After the first and second conference calls, we accepted comments and edits via email from the stakeholders on the list of evidence gaps and PICOTS documents that were discussed during the respective calls. These comments were reflected in changes to the pertinent documents and reflected in the meeting summaries.

Between the first and second calls, we asked the stakeholders to prioritize the revised list of evidence gaps. This exercise was the first round of prioritization, and it was based on the complete list of 29 evidence gaps. The second round of prioritization occurred after the second call, and consisted of only the top tier evidence gaps, or those that were ranked the highest in the first round (Appendix E). The Web-based prioritization exercises allowed each stakeholder to distribute a limited number of star-shaped indicators (referred to as stars in the remainder of this document) to those they viewed as the highest priority gaps. In the first round, we gave each stakeholder a total of 14 stars, which they could distribute among 29 gaps. No single gap could get more than four stars from a single person. In the second round, the stakeholders received nine stars to distribute among 16 evidence gaps, and no one gap could get more than three stars from a single person.

Prior to the second call, we sent the stakeholders the results of the first online prioritization exercise. For the upper tier, or highest-ranking, evidence gaps, we also shared the draft PICOTS. During the second call, we reviewed and discussed the results of the prioritization exercise and asked stakeholders for feedback on the PICOTS and for any thoughts on potential research designs for the upper tier evidence gaps. Following this discussion, we applied the updated PICOTS framework to the upper tier evidence gaps and translated them in to research questions. We then invited the stakeholders to reprioritize the upper tier of the evidence gaps using the same Web-based prioritization tool used in the first round. After the second round of prioritization, we identified the top-ranked research needs as determined by the stakeholders’ prioritization. These are presented in this report as the prioritized future research needs for diagnosis, treatment, adverse events, and prevalence for ADHD.

### Research Question Development and Research Design Considerations

After the second round of prioritization in which the stakeholders ranked the evidence gaps and identified the prioritized research needs, we applied study design considerations to the top-ranked research needs. In considering potential research designs, we concluded that for many research needs more than one research design can be applied. We considered the advantages and disadvantages of different factors for each potential research design over another. Such factors included advantages of the study design to produce a valid result; resource use, size, and duration; potential social, legal, and ethical issues; and availability of data or ability to recruit participants. We did not ask stakeholders to rank study designs or provide input to the proposed study designs, as such an exercise would add considerably to the length and complexity of the process, and some stakeholders might not have the technical expertise to engage in this process. The final list of prioritized research needs was not shared with the stakeholders until the public comment period of the draft report.